# Executive summary

Watersheds in the Wisconsin portion of the Lake Superior basin, specifically those in the red clay plains, are susceptible to degraded water quality from eroding stream banks, which can impact in-stream habitat and result in excessive nutrient loading (WDNR, 2007a). Watershed conservation efforts in the region that seek to improve water quality in streams and rivers have largely focused on restoring and protecting hydrology by “slowing the flow.” Slow the flow (STF) practices seek to reduce peak flows with a watershed-scale hydrologic restoration approach that increases in-channel roughness and sinuosity, surface roughness, water storage in wetlands, and infiltration. Recent efforts have sought to improve implementation of slow the flow across jurisdictions, agencies, land use, and land ownership types, and to identify priorities for conservation efforts across the basin. This report summarizes an extensive literature overview to inform strategic slow the flow efforts in Wisconsin’s portion of the Lake Superior basin. This report focuses on research, monitoring, and management publications covering this region, but also includes work in other areas with similar hydrology, land use, and soils.

This report falls within the context of a long history of stewardship of the landscape and many recent conservation initiatives. The Lake Superior basin in Wisconsin is the traditional, ancestral, and modern home of the Anishinaabe. The Anishinaabe have been stewards of this land for centuries. Through treaties, the Anishinaabe ceded most of the basin to the U.S. in the mid-1800s, retaining rights to forage, hunt, fish, and practice traditional lifeways. Today the Bad River and Red Cliff Bands of Lake Superior Chippewa manage reservations within the Wisconsin portion of the Lake Superior basin, and the Great Lakes Indian Fish and Wildlife Commission works to support treaty rights in the ceded territories. Tribal nations and agencies are crucial partners in the work to manage water quality in the basin.

European land use practices from the mid-1800s to the mid-1900s greatly altered the hydrologic regimes in the basin. In the last 50 years, there have been diverse efforts to address these issues through restoration. The goal of this report is to move towards establishing consistent conservation goals and priorities across the basin based on the best available knowledge, to assist STF practitioners in planning projects. While outside the focus of this report, hydrologic restoration also has important implications for nutrient enrichment, sediment contamination, fish and wildlife habitat, and biodiversity. This report will also help identify synergistic opportunities to address these concerns.

## Report Overview

This report includes background on slow the flow efforts in the Lake Superior Basin, with a focus on bringing together scientific knowledge to form recommendations for best practices. The section titled Recommendations includes STF recommendations for each land type based on a literature review, a framework for a watershed-scale strategic approach, and a discussion of how that framework could be implemented. The report concludes with a discussion of future needs. In Appendix 2, readers can find an extensive literature summary that includes background information about the Lake Superior basin in Wisconsin, including an introduction to the geomorphology, land cover, climate, and hydrology of the basin. This appendix also includes an overview of the relevant scientific literature organized largely by landscape characteristics, including watershed storage (wetlands), surface roughness, forest cover, agricultural, urban, and rural residential lands. These sections provide context for the recommendations provided in the main section of the report. This paper was a part of the Lake Superior Collaborative symposium held on April 29^th^, 2022, where partners were able to provide feedback on recommendations as next steps. This information is captured in Appendix 1, to influence future planning efforts.

## Watershed-scale strategic approach

We recommend a watershed-scale strategic approach to hydrologic restoration whereby priorities for hydrologic restoration are considered within the context of the larger basin so funding and efforts can be focused in subwatersheds and locations where they will have the greatest impacts. We propose a set of parameters and ranking criteria identified from our literature review that constitutes a framework to implement a watershed-scale STF approach. Where available, we identify basin-wide datasets that could be used to implement that framework and prioritize STF efforts in the basin. We also identify data gaps and newly available data that could improve the STF framework.

We recommend the following hierarchical parameters for ranking subwatersheds for STF efforts:

1. Primary Criteria
  1.1 percent storage by subwatershed, and
  1.2 peak discharge/subwatershed area ratio, and
  1.3 percent open land by subwatershed.
2. Secondary Criteria
  2.1 percent of total wetland area with surface water attenuation by subwatershed, and
  2.2 proportion of riparian area not mapped as wetland by subwatershed, and
  2.3 proportion of forested riparian areas of total riparian area by subwatershed
3. Tertiary Considerations
  3.1 locations of inactive farmland,
  3.2 transition zone and soil permeability,
  3.3 downstream coastal ecosystem or habitat type, and
  3.4 land ownership type.

A multicriteria decision matrix could be used to incorporate these multiple metrics to prioritize among watersheds and subwatersheds. Where available, we present the data to do that in the report. However, we also describe additional desktop and field assessments that are needed to develop a complete, holistic decision matrix for prioritizing STF work in the basin.

## Recommended STF Actions

The following list summarizes the recommendations identified based on a review of primary literature and work completed by resource managers. These are described in more detail in the report and the literature review in the report appendix. The report was created with and on the behalf of a broad partnership and published by the Wisconsin DNR. Note that this document does not represent any legal requirements. Some local jurisdictions might have more restrictive recommendations/requirements than what are discussed here, check with your local laws and restrictions when considering the implementation of these practices.

[underlined: Watershed Storage]

- Target wetland restoration efforts to maximize an increase in overall watershed storage, including where wetlands can maximize storage and help desynchronize flows. (This needs to be considered carefully as artificially raising water elevations to provide more storage causes more harm than good).
- Use Height Above Nearest Drainage (HAND) analysis to identify priority floodplain wetlands for restoration and protection.
- Protect high-functioning watershed storage and hydrologic processes in existing wetlands and floodplains.
- Investigate potential opportunities to install wetlands, grassed waterways, and two-stage ditches in agricultural fields.
- Install multiple smaller projects in headwater areas, in parallel along multiple tributaries, for a greater cumulative increase in storage as opposed to restoring a large single site lower in the watershed.
- Design low-tech process-based restoration approaches (Wheaton et al., 2019).
- Design wetland restoration sites to include flow dispersal and grade control structures that enable natural water level fluctuations, rewetting degraded areas with flood pulses and excess flows, and reconnecting other wetland areas to the site and stream channel.

[underlined: Agriculture]

- Pursue opportunities to harness transitional agricultural areas to increase interception, infiltration, and retention.
- Incentivize STF flow practices and non-point source runoff trading.
- Implement best management practices on intensive farmlands.

[underlined: Upland and In-Channel Roughness]

- Map gully type and apply appropriate restoration actions for groundwater- or surface water-driven gullies.
- Implement in-channel work consistent with geomorphic studies, with a focus on low-tech solutions.

[underlined: Urban and Rural Residential]

- Identify and prioritize STF efforts upstream of urban centers that will reduce peak flows and flooding in developed areas.
- Implement bioretention and stormwater management approaches to help protect urban infrastructure.
- Continue assessments to identify and prioritize replacement or upgrades of road-stream crossings that have undersized culverts, are barriers to organism passage, or have eroding soils.

[underlined: Forestry]

- Implement existing guidelines for Forestry BMPs.
- Establish an open lands percentage threshold for hydrology and water quality protection, and establish standard, repeatable methods for assessing open lands by subwatershed.
- Clarify the delineation of the Riparian Management Zones (RMZs) to determine consistent standards for width and allowable practices in RMZs.
- Establish a consistent definition of unproductive steep slopes for private and public lands and promote BMPs at those sites.

[underlined: Receiving Waters]

- Prioritize STF efforts in watersheds that drain to poor fen coastal wetlands.

## Next steps

The multiple land ownership types and land uses in the basin make watershed planning and management challenging. To move forward with our recommendations, we identified several needs. These include continued support and funding for the ongoing monitoring that has informed decisions to date, formal assessment of the effectiveness of past restoration projects and agricultural BMPs, funding for new and ongoing research to understand the impacts of climate change and invasive or nuisance species like emerald ash borer, and improved capacity for data management and sharing.

Also needed are high-resolution land cover, high-resolution hydrologically corrected elevation data (from LiDAR) and an accurate delineation of open lands data, all collected at regular intervals. A basin-wide map of historic and modern ditch networks would also help to inform the prioritization of wetland restoration. Although this report has focused on prioritizing hydrologic restoration, our review of existing knowledge emphasizes the importance of protecting current watershed storage. Efforts to protect high-functioning wetlands and landscapes should also be incorporated formally into any strategic approach.

Lastly, implementing a strategic effort to slow the flow and improve water quality across the basin will require not just maintenance of the many wide and effective partnerships in the basin, but a further broadening of partnerships across industries, disciplines, and agencies.