# Appendix 4 Additional Data for decision making

Table A2.1 Active USGS continuous discharge stream gauges and peak flow gauge sites in Wisconsin’s Lake Superior basin

Summary hydrologic statistics compiles from water year reports on http://waterdata.usgs.gov. *Maximum peak flow values include preliminary data from July 11, 2016 flood event for Beartrap Cr, Tyler Forks, Bad River, and White River.

Stream Gauge Name | ID | Latitude | Longitude | Start Year | Drainage Area mi^2^ | Contributing area mi^2^ | Max peak flow (cfs)* | Annual mean discharge cfs (low, high) | Annual runoff cfs/mi^2^ | Minimum annual 7 day discharge cfs | Baseflow index
USGS Continuous Discharge Stations
Nemadji River Near Superior, WI | 04024430 | 46.63330 | −92.09410 | 1973 | 420 | 420 | 33000 | 381 (138, 786) | 0.9 | 22 | 0.404
Bois Brule River at Brule, WI | 04025500 | 46.53770 | −91.59550 | 1942 | 118 | 118 | 1860 | 170 (129, 223) | 1.4 | 89 | 0.871
Beartrap Creek at U.S. Highway 2 Near Ashland, Wi | 04026390 | 46.60870 | −90.75640 | 2007 | 23 | 23 | 3320 | 19 (6.2, 40) | 0.8 | 0 | n/a
Tyler Forks River at Stricker Road near Mellen, Wi | 04026561 | 46.39460 | −90.59010 | 2011 | 71 | 71 | 2,940 | 90 (63, 113) | 1.2 | 3.9 | n/a
Bad River Near Odanah, WI | 04027000 | 46.48740 | −90.69600 | 1914-1922, | 597 | 597 | 39,200 | 608 (286, 951) | 1.0 | 48 | 0.477
White River Near Ashland, Wi | 04027500 | 46.49720 | −90.90440 | 1948 | 301 | 301 | 8,590 | 273.1 (164, 426) | 0.9 | 68 | 0.684
Whittlesey Creek Near Ashland, Wi | 040263205 | 46.59446 | −90.96310 | 1999 | 38 | 22 | 1010 | 22 (19, 26) | 0.6 | 16 | n/a
North Fish Creek near Moquah, WI | 040263491 | 46.54888 | −91.06210 | 1989 | 65 | 38 | 3740 | 73.8 (57.2, 87.9) | 1.2 | 44.6 | 0.74
Montreal River at Saxon Falls Near Saxon, WI (04029990) | 04029990 | 46.53690 | −90.37990 | 1986 | 262 | 262 | 9880 | 298.6 (161.9, 468,1) | 1.1 | 30 | 0.55
St. Louis River at Oliver, WI. (0402403250) | 0402403250
USGS Peak Streamflow Station
Sand River Tributary near Red Cliff, WI | 04026190 | 46.89990 | −90.95570 | 1959 | 27 | 1 | 624
Sioux River near Washburn, WI | 04026300 | 46.68880 | −90.95070 | 1964 | 34 | 14 | 1620

Table A2.2 Recommendations from federal, state, and regional initiatives on the size of riparian management zones

Source:; National Management Measures to Control Nonpoint Source Pollution from Forestry - US EPA, 2005
RMZ buffer size | Harvest Restrictions | Other
Varies by state - minimum width of 35-50 feet is generally recommended to be effective. A fixed width is recommended or prescribed. A variable width is determined based on-site conditions such as slope. Intermittent and ephemerals need to be given special consideration when determining boundaries. | Recommendations largely related to maintaining stream temperature.; Examples:; - Maintain quantity of trees that provide at least 50% of the summer midday shade.; - Maintain 40% of the total volume of timber >6" DBH over a 10-year period, evenly distributed.; - Maintain one-half the volume of a fully stocked stand. | Extended rotations, go to top of slopes, consider wind-firmness of the leave trees and strips. Leave slash on highly erodible soils. Revegetate bare surfaces with at least 70% or greater coverage. No skidders or other heavy machinery, landings, portable sawmills, and roads in the SMA. Minimize soil disturbance. Restrict mechanical site prep and encourage natural revegetation, seeding and hand planting.
Some states utilize stream type (intermittent, perennial, trout water, public water supplies, etc) and slope to define RMZ size, ranging from 50 - 200 feet. | | Directionally fell trees away from streams and remove slash and debris unless recommended by fisheries. Apply harvesting restrictions in the SMA to maintain its integrity.
Source:; Riparian Forest Buffer (NRCS conservation practice standard, 391)
RMZ buffer size | Harvest Restrictions | Other
Forest Buffer Zone (1): No harvest zone minimum 15 feet wide. | Retain forest cover to provide shade to moderate and stabilize water temperature and contributes necessary detritus and large woody cover to the aquatic ecosystem. | Management limited to bank stabilization and removal of potential problem vegetation. Removal of trees on a case-by-case basis where habitat and water quality values are not compromised.
Forest Buffer Zone (2): Sustainable Management Zone: extends a minimum distance of 20 feet past zone 1. Minimum combined width of zone 1+2 is the lesser of 100 feet or 30% of the geomorphic flood plain. In no case will the combined width of 1+2 be less than 35 feet. | Sustainable timber management is permitted in accordance with the Wisconsin Forestry Best Management Practices, such that the original purpose of the forest buffer is not compromised by loss of vegetation or disturbance.
Forest Buffer Zone (3): Upgradient Grass-Forb Zone: minimum width 20 feet. | | Can be used to control soil movement in the upgradient area immediately adjacent to zone 2. Concentrated flow and sheet and rill erosion will be controlled within 300’ up gradient of the buffer.
Source:; Wisconsin’s Forestry Best Management Practices for Water Quality, Field Manual, 2010
RMZ buffer size | Harvest Restrictions | Other
100 feet for all Lakes, designated trout streams, and streams ≥ 3 feet wide | Harvesting should leave at least 60 ft^2^ basal area in trees 5" DBH and larger, evenly distributed in RMZ. Harvest intervals minimum of 10 years. Develop trees 12" and larger. Use selection harvests and promote long-lived tree species appropriate to the site. No harvest of fine woody material within 50’ of the OHWM. | Operate wheeled or tracked equipment within 15-50’ of the OHWM only when the ground is frozen or dry. Do not operate equipment within 15’ of the OHWM except on roads or crossings. Keep skid trail grades less than 15%, winch logs up steep slopes to prevent erosion.
35 feet for streams < 3 feet wide | Harvesting should leave at least 60 ft^2^ basal area in trees 5" DBH and larger, evenly distributed in RMZ. Harvest intervals minimum of 10 years. Use selection harvests and promote long-lived tree species appropriate to the site. Do not harvest fine woody material within 15’ of the OHWM. | Operate wheeled or tracked equipment within 15’ of the OHWM only when ground is frozen or dry. keep skid trail grades less than 15%, winch logs up steep slopes to prevent erosion.
35 feet for streams < 1 foot wide | No minimum BA residual recommended. Do not harvest fine woody material within 15’ of the OHWM. | Operate wheeled or tracked equipment within 15’ of the OHWM only when ground is frozen or dry. keep skid trail grades less than 15%, winch logs up steep slopes to prevent erosion.
Source:; Management Recommendations for Forestry Practices on Wisconsin’s Lake Superior Red Clay Plain - WI DNR Forestry Division, June 2007
RMZ buffer size | Harvest Restrictions | Other
100 feet on perennial navigable streams; 35 feet on intermittent and non-navigable streams. | Maintain a minimum residual basal area of 80 ft^2^ in trees 5 inches diameter at breast height and larger of long-lived shade tolerant species in riparian areas. | Identify, protect, and create large woody debris in headwater streams. Consider layout so that uncut stands can intercept runoff from harvested areas. Do not concentrate clear-cuts or new roads in a watershed or in erodible areas, such as steep slopes. Improve stocking of species that can be harvested by individual or group selection with long rotation ages; selective harvests should be a minimum of 15-20 years apart. Other considerations given as to effects of different harvesting methods.
| Maintain a minimum residual basal area of 60 ft^2^ in trees 5 inches diameter at breast height and larger of long-lived shade tolerant species outside riparian areas.
Source:; Management Recommendations for Forestry Practices along Wisconsin’s Coastal Trout Streams - WI DNR Forestry Division, June 2007
RMZ buffer size | Harvest Restrictions | Other
100 feet on perennial navigable streams | | Leave dead and down on all streams. Do not remove all large trees along streams. Identify, protect, and create large woody debris in headwater streams.
Appendix B: minimum of first 50 feet beyond OHWM | VERY limited selective harvesting leaving at least 90 ft2 of basal area in long lived species. Manage for large woody debris recruitment. | NO heavy equipment, promote conifer, large diameter, long-lived and down woody debris. In hardwood increase conifer component by hand planting if site allows.
Appendix B: within 50-200+ feet of OHWM | Leave at least 50 ft2 or at least 50% canopy cover. | NO rutting or scarification (ops during frozen ground), promote long lived species especially conifers, avoid clearcutting, use selective harvests or small patch cuts, manage on a longer rotation (20-25 years cut rotation), others.
Source:; Erosion and Sedimentation in the Nemadji River Basin - Nemadji River Basin Project Final Report, 1998
RMZ buffer size | Harvest Restrictions | Other
Width of riparian zone in red-clay portion of the watershed includes the entire floodplain plus adjacent slopes 20% or greater. | Thin stands to encourage large crown development. Immediately adjacent to stream, design for trees 30 feet apart. From 30 - 100 feet from the stream, design for trees 20-30 feet apart. | Manage for large, woody debris. Plant long-lived deciduous and coniferous trees in sparsely forested areas. Retain conifer and deciduous mix throughout riparian zone, favor long-lived trees, selective harvest for later successional species. Encourage diverse, complex landscape. Coordinate management between landowners, agencies. Take precautions to avoid blocking floodplains when building a road across a stream.
Source:; Bayfield Peninsula Stream Assessment
RMZ buffer size | Harvest Restrictions | Other
Maintain riparian buffers consistent with June 2007 WI DNR Management Recommendations for Forestry Practices on WI Lake Superior Red Clay Plain. Restrict timber harvest within 100 feet of perennial and navigable intermittent streams. | Manage for large woody debris recruitment to the stream channel | Restrict harvest on slopes >10%; maintain 100 selective cutting buffer near edges of high terraces to prevent slope erosion.
No harvest within 50 feet of non-navigable streams; Selective harvest only within 300 feet. | | Encourage pre settlement species composition, with emphasis on white pine. restoration in riparian and headwater zones.
100-foot selective cut buffer from edge of high terraces.
Source:; Best Management Practice Guidelines for the Wisconsin Portion of the Lake Superior Basin - Project Sponsors: Ashland, Bayfield, Douglas, Iron County Land Conservation Committees and WI DNR, Schultz, SD 2003. Riparian Information in the Habitat Section of document, see diagrams on pg. 29, 23, 24
RMZ buffer size | Harvest Restrictions | Other
Slopes < 10%: | Maintain minimum residual basal area of 80 ft^2^ IN riparian area, maintain minimum residual basal area of 60 ft^2^ OUTSIDE riparian areas. | Leave dead and down trees in the riparian area. Manage for a component of 50–200-year-old trees. Maintain a mature forest condition by encouraging older successional forest - high canopy, conifer understory, vertical structure, and woody debris. No wheeled or tracked equipment, only limited harvest for personal use allowed, use hand planting. Target permanent long-lived tree species to maintain soil stability, filter pollutants, provide shade for streams and slow melting of snow along streams.
0-50 feet from OHWM | NO timber harvest allowed, only limited harvest for personal use allowed.
50-90 feet from OHWM | Winter harvest, operate only small equipment, encourage older succession forest, selective harvest.
Slopes >10%:
0-75 feet from OHWM | NO timber harvest allowed under county zoning. Maintain permanent long-lived tree species for soil stability, filter pollutants, provide shade for streams and slow melting of snow along streams. | Identify and avoid operating in intermittent drainages and streams.
75-100 feet from OHWM; Riparian guidelines must include small non-navigable streams and dry channels. | No harvest preferred on these slopes, however limited harvest of areas on the inside of a stream meander (where erosion is not occurring) can be done to encourage preferred forest composition. Encourage older succession forest. Selective harvest should be a minimum of 15-20 years apart. Retain stream shade. | Identify and avoid operating in intermittent drainages and streams. Operate only small equipment (ATV comparable). Fence setbacks. Accelerate shoreland buffer restoration by planting native plant species. Others.