# Appendix 3 Methods for comparison of open lands methodology

There are several widely produced land use/land cover datasets. We reviewed the following datasets to evaluate if they could support evaluation of open lands to prioritize slow the flow work in the south shore basin.

- National Land Cover Database 2011 (NLCD - https://www.mrlc.gov/)
- WiscLand 2 (http://dnr.wi.gov/maps/gis/datalandcover.html)
- National Agriculture Statistics Service CropScape Cropland Data Layer (CropScape - https://nassgeodata.gmu.edu/CropScape)

The National Land Cover Database (NLCD) is a broad land cover database for the nation, with relatively limited land use classes compared to both WISCLAND and CropScape. It also has limited ground-truthing as it covers the entire country. WISLCAND 2 was developed as a broad land use/land cover database for the state of Wisconsin. Because of the smaller scale, WISLAND 2 and has higher levels of quality control and ground truthing compared to both NLCD and CropScape. It includes more classes for forest type, while CropScape is broken out into more classes of crop type than WISCLAND or NLCD. CropScape is designed for managing agricultural lands. WISCLAND is superior at mapping at a fine scale: it identifies entire fields as a single land use, while CropScape has a very grainy/patchy output which limits its use at a fine scale. The three datasets differ in their methods and outputs for identifying shrubland, woody wetlands, and deciduous forest, all of which are present in the south shore basin. WISCLAND is not reproduced or updated on a regular basis, but as needed. WISCLAND 1 was developed between 1991 - 1993 and updated to WISCLAND 2 in 2014. There are no current plans to update WISLCAND 2. NASS CropScape is produced every year from satellite data. NLCD is designed to provide updates every five years (this review considered NLCD 2011, but the most recent iteration is NLCD 2016).

We found NLCD has limited utility for evaluating open lands in the South Shore basin due to the limited number of classes and low resolution and quality assurance measures. While WISCLAND 2 is likely more accurate due to extensive ground-truthing and quality assurance, it is now five years old, and not currently planned to be updated. While CropScape has less quality assurance and is likely less accurate, it is produced annually, which allows us to potentially conduct a similar analysis to look at open lands in the last 15 years to identify harvests/young forest. That would not be possible with WISCLAND or NLCD. So, we used CropScape to identify open lands and compared those to the outputs from the Community GIS analysis. We compared the results of using each dataset to summarize percent open lands by subwatershed, and to evaluated how effective each method is at identifying different types of open lands: urban, agriculture, and young forests. Because the most recent Community GIS assessment for the entire south shore was done in 2008, but a more recent assessment was done in the Nemadji in 2014, we chose to use the more recent 2014 Nemadji assessment for this comparison.

While neither analysis is ground-truthed extensively in the region, the CropScape is a national data layer with limited quality assurance at the regional or local scale. The regional Community GIS analysis included extensive heads-up digitization of individual parcels of open lands from multiple satellite imagery for each year in the series and is therefore assumed to be a more accurate dataset. However, because of the lack of ground-truthing, it is impossible to assess how accurate the Community GIS analysis is.

First, we reclassified the CropScape dataset to aggregate the categories to open, forest, wetland, or other (Table 7). We then merged the 2007 – 2014 CropScape data into a single layer that identifies all lands that was classified as open in any year from 2007 to 2014. This step intends to include lands that were harvested but re-forested as young forest less than 15 years in age. While CropScape data go back to 2003, we chose to only use 2007 – 2014. Prior to 2007, CropScape data is not as robust, and the overall dataset only goes back to 2003. We chose to only use layers produced after methods used to derive CropScape layers improved in 2007 (https://www.nass.usda.gov/Research_and_Science/Cropland/metadata/meta.php).

Next, we found the percent open lands by subwatershed, based on the CropScape data. Because we wanted to have a direct comparison to the Community GIS Open Lands assessment, we summarized using the same subwatersheds delineated for the Community GIS assessment. For a qualitative assessment of the effectiveness of the CropScape data to identify young forest and recent harvests, we overlaid the reclassified CropScape data with the three classes (harvested, urban, and agriculture) of open lands parcels digitized in the Community GIS analysis. We did this both for an individual year, 2014; as well as for the cumulative open lands based on 2007 – 2014 data.

Table A1.1 All CropScape classes present in the south shore basin and how each was reclassified for comparison to the Community GIS analysis

CropScape class name | Reclassified class name | CropScape class name | Reclassified class name
Background | Other | Fallow/Idle Cropland | Open
Corn | Open | Forest | forest
Sorghum | Open | Apples | forest
Soybeans | Open | Christmas Trees | forest
Sunflower | Open | Clouds/No Data | other
Sweet Corn | Open | Developed | Open
Barley | Open | Water | wetland
Durum Wheat | Open | Wetlands | wetland
Spring Wheat | Open | Nonag/Undefined | Other
Winter Wheat | Open | Aquaculture | Other
Other Small Grains | Open | Open Water | wetland
Dbl Crop WinWht/Soybeans | Open | Developed/Open Space | Open
Rye | Open | Developed/Low Intensity | Open
Oats | Open | Developed/Med Intensity | Open
Millet | Open | Developed/High Intensity | Open
Canola | Open | Barren | Open
Flaxseed | Open | Deciduous Forest | forest
Safflower | Open | Evergreen Forest | forest
Alfalfa | Open | Mixed Forest | forest
Other Hay/Non-Alfalfa | Open | Shrubland | Open
Camelina | Open | Grass/Pasture | Open
Sugarbeets | Open | Woody Wetlands | wetland
Dry Beans | Open | Herbaceous Wetlands | wetland
Potatoes | Open | Triticale | Open
Other Crops | Open | Vetch | Open
Misc Vegs & Fruits | Open | Dbl Crop WinWht/Corn | Open
Onions | Open | Pumpkins | Open
Peas | Open | Dbl Crop Barley/Sorghum | Open
Herbs | Open | Dbl Crop Soybeans/Oats | Open
Clover/Wildflowers | Open | Blueberries | Open
Sod/Grass Seed | Open | Cranberries | other