# Appendix 2 Background and additional information regarding Lake Superior’s watershed

Wisconsin’s portion of the Lake Superior basin covers 2 million acres or approximately 3,070 square miles (Turville-Heithz, 1999) and is bound by Lake Superior to the north at an elevation of approximately 183 meters and the continental divide between the Mississippi/Gulf of Mexico drainage to the south at an elevation of approximately 549 meters.

## Bedrock and glacial geology

The Lake Superior basin was created during a period of extension known as the Midcontinent, or Keweenawan Rift about 1.1 billion years ago. The rifting resulted in [underlined: the] deposition of volcanic rocks varying from rhyolite to basalt, including flood basalts that can be seen along the north shore of Lake Superior (Miller and Nicholson, 2013). As rifting activity declined, a thick sequence (up to 7km) of Paleozoic sedimentary rocks were deposited in the region, including the Upper Keweenawan Bayfield sandstones that can be seen along the south shore of Lake Superior (Cannon et al., 1999; Nicholson, 2006).

Glacial action is largely responsible for the relief of Wisconsin’s Lake Superior basin and forms the foundation over which land cover and the hydrologic network became established. The landform in the basin is strongly influenced by more recent pulses of glaciation during the Quaternary when the Laurentide Ice Sheet occupied the Keweenawan Rift Basin (Syverson and Colgan 2004). The most recent stage of the ice sheet, the Wisconsinan, occurred approximately 75,000- 9,500 radiocarbon years before present (BP). During the Wisconsinan stage, the Superior lobe advanced and retreated from the northeast to the southwest numerous times, carving the Lake Superior basin coincident with a portion of the Keweenawan Rift.

Five major phases of the Superior lobe have been identified based on local stratigraphy: the St. Croix, Automba, Split Rock, Nickerson, and Marquette phases (Need and Johnson, 1984). Earlier phases are not recorded in the sedimentary record due to the re-working of material by the ice sheet after subsequent advances. Each phase advanced less extensively to the southwest and deposited associated ground moraines (blankets of glacial till covering the landscape), end moraines at the furthest point of advance, and outwash deposits (Wright, 1971). Successive advances of the Superior lobe resulted in the deposition of glacial tills consisting of redder, more fine-grained sediments. During periods of retreat, proglacial lakes formed between the front of the ice lobe and the end moraine; and deposited fine-grained sediments in deep lacustrine environments and coarse-grained sediments in high-energy shoreline environments (Wright et al., 1969).

During the Marquette Phase, the final re-advancement of the Superior Lobe, about 9,900 years BP, the ice advanced to the Thompson and Nickerson moraines, which were formed during the prior Nickerson phase. As the ice sheet advanced, thick layers of till were deposited on top of the reworked lake and beach sediments were deposited in the proglacial lake during the retreat of the earlier Nickerson phase. As the ice retreated, a proglacial Lake Nemadji formed, draining to the south through the Portage Outlet, at the western edge of the present-day Nemadji watershed. The lake level at that stage was 1100 – 1150 ft. Once ice retreated further, Lake Nemadji coalesced with Lake Minong to the east and water began draining to the south along the lower Brule River outlet (Clayton, 1984, Carney, 1996). At this stage, the water level was 325 meters, and the proglacial lake is referred to as Glacial Lake Duluth. As the ice retreated further to the northeast, an outlet to the east through the St. Laurence Seaway eventually opened, resulting in a dramatic decrease in lake level to about 122 meters (Wright, 1971, Farrand, 1969).

Because of the repetitive advances of the Superior Lobe and subsequent proglacial lakes, the deposits along the southern margin of Lake Superior consist of interbedded ground and end moraine tills that become finer and redder up-section; beach and outwash sands and gravels; and red lake clays. Glacial advances into proglacial lakes reworked lacustrine deposits, making it difficult to distinguish between lacustrine clay and clay till (Olcott et al., 1978). The red clay plain blankets the area from Lake Superior inland for 8 – 20 miles throughout Wisconsin, with thin deposits near bedrock outcrops to deposits over 182 meters thick in lower parts of the watershed. In the upper watershed, a mix of glacial drift and glacial till results in soils that range from well drained to somewhat poorly drained and a greater proportion of sandy loam textures.

The base level for South Shore streams is defined by lake levels in Lake Superior, which dropped by 45 m during the Lake Minong phase (Breckenridge, 2013). The sudden drop in base level may have caused the tributaries of Lake Superior to incise their channels into the glacial tills and lacustrine sediments, carving steep-walled valleys, and dissecting the landscape (Breckenridge, 2013). The retreat of the Laurentide ice sheet has resulted in an isostatic rebound of the depressed continental crust, and an ongoing rise in base level for South Shore streams (Tushingham, 1992). Rates of isostatic rebound were fastest immediately after glaciation and have slowed since then (Neff and Nicholas, 2005). Rates are higher where the ice was the thickest in the northeastern portion of the Lake Superior basin (Neff and Nicholas, 2005). Lake Superior’s outlet at Gros Cap on the northeastern side of Lake Superior experiences an average predicted uplift rate of 36 cm/century, while the southwestern end of Lake Superior in Duluth experiences about 5 cm/century (Tushingham, 1992). The current base level of about 183 meters was reached at about 5,500 BP. The rise in base level and tipping effect of isostatic rebound, with faster rates to the northeast, has resulted in the drowning of the river mouths of tributaries flowing into Lake Superior from the south. These shallow, drowned river mouth conditions resulted in the flooding of incised river valleys, and the presence of estuaries and coastal wetlands like Bark Bay and Fish Creek Slough along the southern margin of Lake Superior.

The soils in the south shore area are mainly derived from glacial deposits derived directly from ice transport, or indirectly from meltwater or wind transport (Schaetzl, 2015). Alfisols dominate in the coastal areas of Lake Superior, shown in Figure 2 as forested, red, clayey, or loamy soils (Schaetzl, 2015). Aquic soils, with low permeability and minimal runoff, are generally restricted to wetland areas (Schaetzl, 2015). Most bedrock is either buried by glacial drift or scraped clean by ice (Schaetzl, 2015).

Figure 2 Soil Regimes of Wisconsin

(from WDNR, 2015b).

The hills in the central portion of the Bayfield Peninsula are covered with 15-30 meters of glacial drift (WDNR, 2010), with some areas up to 182 meters of outwash material, primarily sand or sand mixed with gravel. This area is referred to as the Northwest Sands. Soils here drain rapidly, and as a result, 161 mi^2^ in the central Bayfield peninsula does not contribute to surface runoff (Fitzpatrick et al., 2015; Figure 3) and is considered the primary groundwater recharge area in the region (Fitzpatrick et al., 2015). Cooper Falls and Miller Creek soil formations, sandy till material, and clayey glaciolacustrine deposits, respectively, overlay Bayfield group bedrock (Goebel et al., 1983; Clayton, 1984). These deposits are tens to hundreds of meters thick in the highlands and thin as they near Lake Superior (Fitzpatrick et al., 2015). Where the Miller Creek Formation is present it overlays both Cooper Falls and Bayfield bedrock (Fitzpatrick et al., 2015). The clayey Miller Creek deposits and sandy Cooper Falls formations are differentiated by a set of relict shorelines from glacial Lake Duluth (Fitzpatrick et al., 2015). In some areas Miller Creek deposits may have been removed by the wave action of Lake Duluth, exposing older Copper Falls deposits of sandy till or stream/shoreline sand and gravel (Clayton, 1984).

Figure 3 A schematic cross-section of the geology and groundwater flow patterns across the Bayfield Peninsula

Figure from Fitzpatrick et al., 2015.

## Land cover

An understanding of land use in Wisconsin’s portion of the Lake Superior basin since European settlement can help us understand associated hydrologic changes. However, returning to pre-settlement conditions is not feasible and is not a management objective for most areas in the Lake Superior basin.

Native American tribes have inhabited the region for centuries. The Ojibwe people migrated from eastern North America to the northern Great Lakes region in the late sixteenth or early seventeenth century (Danziger 1979). When they arrived in the area, the Ojibwe established economies and lifestyles based on forest and wetland resources, including paper birch, which was used for canoe building, sugar maple, woodland game, wild rice beds, fur-bearing mammals, fish, and small-scale, and semi-permanent gardens, which shaped the areas they lived in (Steen-Adams et al., 2011). While the impact that the Ojibwe way of life had on the landscape in the Lake Superior basin was much less than that of European settlers, they did transform the lands that they settled (Steen-Adams et al., 2011).

Pre-European settlement land cover was a mosaic of forest types dominated by mixed conifer-deciduous forest (Figure 4). The red clay plain was historically covered with boreal forest containing white spruce, white cedar, balsam fir, and white pine and mixed conifer forests of hemlock, sugar maple, yellow birch, and white pine (WDNR, 2010). Birch-aspen forests were present, with conifer bogs and wetland communities more common in upper watershed areas.

European settlers migrated to the region in the mid to late 1800s and began clearing forests for timber. After the cutover of Lake Superior basin forests in the late 19^th^ and early 20^th^ centuries by European settlers, immigrants moved to the region to begin farming. Settler land use practices (extensive historic logging, intense burning, and agriculture) resulted in the conversion of most boreal forests to aspen-dominated communities (Figure 5, WDNR, 2015a). Throughout the northern portion of the state including the Lake Superior basin, forest composition still reflects the legacy of European settlement. For example, hemlock and white pine forests have declined in the area from 22% to 1% since European settlement (Rhemtulla et al., 2009). The structure of the forests also shows substantial differences from pre-settlement times. The proportion of medium- and large-diameter trees of all species has declined from 71% to 27% (Rhemtulla et al., 2009).

Settlers found that the short growing season and challenging soils made farming difficult in the region. The number of farms and area of land in agricultural production in the region peaked in the 1920s and has been declining since then, with significant reversion to forestland and no widespread forest clearing since then (Krog, 1996). The first farms to fail were those located on the well-drained, sandy glacial tills along the margin of the Superior Clay Plain. These soils had very low organic matter and were prone to significant crop loss in dry years. After spring and fall rains, it can take 5-7 days, even with engineered drainage, for Clay Plain fields to dry enough to till. As a result, agriculture in the clay plain is dominated by perennial forage production that does not require an early-spring seeding or a late-fall harvest when soils are most challenging. Of the 52,000 cropland acres in Bayfield County, 87% are in grass hay, alfalfa, clover, or pasture (USDA, 2015). Although the soils and climate are conducive to producing high-quality forage, hay, beef, and dairy, enterprises have struggled to compete in the low-price commodity markets and the number of farms, particularly dairy farms, continues to decline. In Bayfield County, the most farmed county in the Wisconsin portion of the Lake Superior basin, there were 850 total farms in 1970, but by 2017, the number had declined to 427. There were 112 dairy farms in 1992 and fewer than 30 still in operation in 2015 (NASS 2012).

Agricultural production in the Lake Superior Basin is now concentrated in a few areas: along state highway 169 in Ashland and Iron County, the Marengo Valley near Ashland, the Benoit and Mason areas and between Iron River and Port Wing, and north of state highway 2 in Douglas County. Like elsewhere in the Upper Midwest, this remaining production is increasingly concentrated in large farms. From a watershed management standpoint, this means that management decisions by individual farmers have a significant local impact on the watershed. This potentially makes efforts to implement conservation practices more efficient as there are fewer managers to work with. All the Land and Water Conservation plans for the four counties across the basin identify slowing the flow of agricultural lands as a priority (Douglas County, 2009, Bayfield County, 2010, Ashland County, 2010, Iron County, 2010).

Figure 4 Pre-Generalized map of pre-settlement vegetation map of the western Great Lakes region

Note the prevalence of boreal forest and conifer swamps in the Lake Superior clay plain (see Figure 2).

Map from Sisk, 1998.

Figure 5 Contemporary vegetation map of the western Great Lakes region forest of the Lake Superior basin

Note the modern prevalence of aspen-birch forest on the Lake Superior clay plain (see Figure 2).

Map from Sisk, 1998.

The xeric, well-drained soils of the Northwest Sands in the central part of the Bayfield Peninsula historically supported jack pine, white pine, and red pine barrens (Figure 4); this fire-prone landscape also supported scrub oak. Fire in this landscape was historically ignited by lightning. Ojibwe also used fire to enhance berry production (Martin, 2019). Today, the lack of fire on the landscape along with other land use practices (grazing by cattle and deer, rural development, and plantation forestry), has resulted in the conversion of these formerly pine-barren communities to forested communities (WDNR, 2015a).

## Climate change projections

The Wisconsin Initiative on Climate Change Impacts (WICCI) Climate Working Group’s downscaled climate models predict increases in air temperature under high and low emissions scenarios for the state. These models predict an increase in the average number of days per year with a minimum temperature of 21°C from 0 days (1981-2010) to 5 days (2041-2060) (Figure 6). WICCI (2011) projects an increase of 2 to 5°C by the mid-21st century, with most of this warming in winter (Figure 6). Overall, Wisconsin has become 1.2°C warmer since the 1950s (dnr.wisconsin.gov/climatechange/science). Air temperature projections mean changes in evaporation and transpiration which affect hydrologic patterns. The rate of warming may outpace the rate at which ecosystems are able to migrate and adapt (Loarie et al., 2009). An updated report was released in 2022 and analyses of historical climatic changes over the last 10 years, especially seasonal warming, precipitation changes, and increases in extreme climatic events, are qualitatively consistent with expectations from WICCI’s 2011 Assessment Report. A few of the major takeaways from the updated report are that winters are warming more rapidly than any other season, and nighttime temperatures are rising more than daytime temperatures. It is anticipated that by mid-century, the number of extremely hot days (32°C or higher) in Wisconsin is likely to triple, and the frequency of extremely warm nights (low temperature of 21°C or above) is projected to quadruple.

Figure 6 Maps comparing rain and temperature for historical data modeled future conditions

(Figure from WICCI, 2022).

Precipitation occurs rather evenly throughout the year in Wisconsin’s Lake Superior basin, with some spatial variation across the basin in the amount of precipitation and the distribution of precipitation as snow or rain. Based on a 30-year record from 1981 – 2010, precipitation as snow occurs throughout the area generally from November through March and is greater in the eastern portion of the basin and at higher elevations. Snowfall averages 139 cm near Superior, WI at the west end of the basin and 422 cm near Hurley, WI, near the east end of the basin (NOAA and NWS, 2021). WICCI (2013) models project a 20 – 30% decrease in the amount of precipitation falling as snow by 2090 for the Ashland, WI area.

Based on a 30-year record from 1981 - 2010, the amount of average annual precipitation increases from west to east, with 78 cm per year at Superior and 92 cm per year near Hurley (NOAA and NWS, 2021). Individual studies on trends in precipitation patterns vary based on the period evaluated and the scale of the analysis. WICCI (2011) examined precipitation trends throughout Wisconsin from 1950 – 2006 and observed an increase in precipitation in the Chequamegon Bay area; in the eastern and western portions of Wisconsin’s Lake Superior basin annual precipitation decreased during the same period. Annual precipitation in the southern part of the basin has decreased by 10-20 percent from 1980-2009, which included a period of drought from the late 1990s through the late 2000s (Fitzpatrick et al., 2013). The frequency and magnitude of large precipitation events in the region are projected to increase due to an increase in atmospheric moisture content. In Wisconsin’s portion of the Lake Superior basin, models estimate 11 – 14 additional ≥2.5 cm rain events, ≥4 additional 5 cm events, and 1 – 2 additional ≥7.6 cm events annually (WICCI 2011). Perica et al. (2014) calculated an increase of up to 9 cm in 24-hour rainfall for 100-year recurrence interval events. Saunders et al. (2012) examined the number of ≥7.6 cm rain events in Wisconsin by decade, starting in 1961. They observed a 92% increase in the number of such storms over time and a 100% increase in the volume of precipitation during storm events. These expected changes in climate and precipitation will have impacts on seasonal hydrology and streamflow in the basin.

## Hydrology and streamflow

Streams in the study region generally flow from south to north toward Lake Superior. The density of intermittent stream channels is lower in headwater areas than in the clay plain (Figure 7). Relic shorelines from glacial Lake Duluth occur at altitudes of 274 – 335 meters. This area contains wave-planed topography of sand deposits over the clay-rich glaciolacustrine Miller Creek formation soils that separate the lower clay plain from the headwater areas of the basin. A series of short steep stream channels occur in the geologic transition zone between the lower clay plain and upper areas of the basin (hereafter, geologic transition zone; Figure 7). In many areas, low-order stream channels in the geologic transition zone are intermittent; in a few areas (for instance, the western Marengo Basin) networks of groundwater-fed streams occur. In the Bayfield peninsula area, this zone separates the surface water contributing areas from the non-contributing areas of the watershed, because the sandy soils at higher elevations (the Northwest Sands, Figure 7) do not contribute to surface runoff (Figure 3).

The USGS maintains nine active gauging stations for measuring discharge and two that record peak flows in Wisconsin’s Lake Superior basin (Table 1 of Appendix 4, Figure 8). Northland College initiated streamflow monitoring at 15 sites in tributaries that drain to the Bad River and Chequamegon Bay in 2013 and 2014, including one site previously monitored by USGS (Table 1, Figure 9). Streamflow data from these gauges show that hydrology generally reflects seasonal precipitation patterns, even among streams that are fed to different extents by snowmelt, surface runoff, and groundwater. As described by Swanston et al. (2010), winter is a period of low stream discharge with most water stored as ice or snow. Spring snowmelt and rain result in high-flow events, typically in April and May. The magnitude of these events is determined by the amount of snowpack and the rate of melt. Rain on snowpack can lead to rapid snowmelt during this time. The highest flow events of the year often occur during spring runoff periods (Figure 10).

Figure 7 Stream networks in Wisconsin’s portion of the Lake Superior basin

Red Clay Plain and Northwest Sands are land-type associations classified in WDNR (2015).

In the summer, base flows are generally lower because of high evapotranspiration, with runoff from occasional rainstorms increasing discharge. Heavily groundwater-fed streams like the Brule River and the streams draining the Bayfield peninsula (Fitzpatrick et al., 2015) experience higher base flows relative to Spring high flows (Figure 10). Lower evapotranspiration rates in fall result in higher base flow. Approximately a third of annual precipitation contributes to surface water streams, with the other two-thirds supporting evapotranspiration (Swanston et al., 2010).

Figure 8 Active USGS stream gauge locations in Wisconsin’s portion of the Lake Superior basin

Table 1 Active discharge gauges operated by Northland College in the Bad River/Chequamegon Bay region of Wisconsin’s Lake Superior Basin

Stream Gage Name | Gauge ID | Latitude | Longitude | Start Year
North Fish Creek near Moquah, WI | NF02 | 46.54888 | −91.0621 | 1989
Sioux River at Big Rock Rd | SXBR | 46.70999 | −90.9258 | 2014
Thompsons Creek at W Bigelow St | TCBS | 46.66653 | −90.9155 | 2014
Bono Creek at Bjork Rd | BCBR | 46.63359 | −90.9477 | 2014
Bay City Creek at HWY 13 | BCC | 46.5816 | −90.8748 | 2013
Little Sioux River near Friendly Valley Rd | LTLS | 46.72677 | −90.9072 | 2014
North Fish Creek at Hwy 2 near Ino | NF2I | 46.53004 | −91.1479 | 2014
Pine Creek at Old US Hwy 2 | PCO2 | 46.5492 | −91.0633 | 2014
South Fish Creek at Colby Rd | SFCR | 46.54061 | −91.0112 | 2014
Unnamed Tributary to North Fish Creek at Hwy 2 | NFT2 | 46.52955 | −91.1222 | 2014
Unnamed tributary to South Fish Creek at Colby Road | SFTC | 46.5306 | −91.0108 | 2015
Tyler Forks River at Caroline Lake Rd | TGCL | 46.27724 | −90.5034 | 2013
Bull Gus Creek at FR703 | BGC | 46.30304 | −90.506 | 2013
Devils Creek at Lake Dr | DVLK | 46.31827 | −90.5808 | 2013
Javorsky Creek at Hwy 77 | JV77 | 46.34133 | −90.517 | 2013

Figure 9 Generalized watershed regions defined by soil conditions and Northland College active stream gauge locations in the Bad River/Chequamegon Bay region of Wisconsin’s Lake Superior basin

Red Clay Plain and Northwest Sands are land type associations classified in WDNR (2015).

Figure 10 Mean of the mean daily streamflow from 1973 – 2015 for 3 major gauged tributaries to Lake Superior in Wisconsin

Patterns in streamflow vary over years across the Lake Superior Basin. Due to climate change, the annual highest peak flow events are increasing during summer storms rather than during spring runoff (Figure 11). For example, in the Bad River, peak flow data are available from 1915 - 1921 and 1949 - present (no data are available from 1922 - 1948). The highest annual peak flow events occurred most often in April and May and never occurred later than July 4th during the time periods 1915 - 1921 and 1950 - 1969. From 1970 - 2009, approximately a quarter of peak flow events occurred after July 4th during late summer or fall. From 2010 - 2016, 3 of 7 peak flow events occurred during the summer months. These summertime high-flow events may displace young-of-the-year fish from optimal rearing habitats.

Existing climate models forecast changes in precipitation patterns across the assessment area, and there are multiple lines of evidence that climate change will continue to alter streamflow patterns (Janowiak et al., 2014). Precisely how these changes to streams will manifest is poorly understood and will likely depend on the interaction of multiple factors. Two studies predict that climate change will lead to more winter rain and earlier peak streamflows (Croley, 2003; Lenters, 2004), which contradicts the trends observed above in the Bad River.

Figure 11 Frequency of annual max flow events by date in the Bad River, WI Wisconsin from 1915-2016 (USGS stream gage data)

Events are stacked to show the total number of events occurring within a two-week period starting on the date listed.

## Low flow hydrology

Low flow occurs during periods of prolonged lack of precipitation and high evapotranspiration. The magnitude and duration of low flow conditions affect the quality and availability of stream habitats during dry periods of the year. Shaake and Chunzhen (1989) suggest that climate change may have the greatest effect on the low flow period of the annual hydrograph because stream ecosystems are most vulnerable to increases in water temperature during low flow periods during late summer months. Based on a doubling of atmospheric carbon dioxide, Eaton and Scheller (1996) predicted that habitat for cold and cool water stream fish would be reduced by ~50%, with the greatest habitat loss in the central Midwest.

Hydrology during periods of low precipitation depends on base flow, or the total groundwater and other sub-surface discharge to streams. Base flow provides cold refugia to fish during warm seasons with low precipitation. Base flow is strongly influenced by subwatershed geology and geomorphology (Fitzpatrick et al., 2015). Primary factors that influence baseflow include stream connection to the water table, enough seasonal recharge to maintain that connection, and hydraulic conductivity (Smakhtin, 2001). These geologic factors vary greatly across Wisconsin’s Lake Superior basin, creating variable stream conditions in the area. In some streams, wastewater discharges may augment base flow, which can aggravate water pollution problems during low flow periods. However, more data and monitoring are needed to investigate this issue in the study area.

Gebert (1979) described low-flow characteristics for Wisconsin’s Lake Superior basin tributaries. He evaluated three analysis methods for calculating 7-day low flow estimates at 2-year and 10-year recurrence intervals at gauged sites and two types of ungauged sites, depending on the amount of low-flow discharge measurements recorded. For sites with limited discharge measurements, drainage area, basin storage, drift thickness, transmissivity (the product of drift thickness and rate of water movement by drift type for clay, moraine, sand, or outwash), and base flow index (discharge at the 90 percent flow duration) were found to be the most significant characteristics in explaining the differences in low flow. The standard error for the estimates was moderately high compared to other basins in the state, which he attributed to large variations in groundwater inflows depending on geologic or aquifer characteristics.

Gebert et al. (2011) estimated base flow that ranged from 0.01 to 8 cubic meters per second (cms) across 79 sites in the Lake Superior basin using continuous record streamflow gauging stations and partial record sites that measure only during low flow conditions. They also calculated the base flow index for those sites. The base flow index is the ratio of the volume of base flow to total runoff volume for the water year A relatively high base flow index indicates high groundwater recharge. A lower base flow index value indicates a greater contribution of surface water runoff to discharge, usually associated with lower infiltration rates. Base flow indices were highest in streams draining the Bayfield peninsula, and generally lower at the eastern and western edges of Wisconsin’s portion of the basin. This is consistent with Fitzpatrick et al. (2015) who reports hydraulic conductivity metrics of the sand-rich Copper Falls Formation of the Bayfield peninsula that are double those of the glaciolacustrine deposits of the Miller Creek Formation in the clay plain. Major recharge zones may be at a slightly higher elevation for the Cranberry and Bark River areas of the north/western side of the peninsula than for the Sioux and Whittlesey Creek area on the east side of the peninsula (Interfluve, Inc. 2003).

Gebert et al. (2016) examined streamflow trends in the Bad River, from 1915-2008 and for a partial record from 1969-2008. They found no significant change in annual 7-day low flow or annual average flow over the full 66-year record at that site, nor did they find significant trends in the data in the partial record since 1969. However, in comparing the 1915-1968 and 1969-2008 records for the Bad River, they did find a significant increase of 14-16% in annual 7-day low flow discharge between periods. This change observed was smaller than the increase observed in most other watersheds (particularly agriculturally dominated watersheds) examined in the study. Conversely, Fitzpatrick et al. (2013) noted a decrease in annual mean flows of over 30 percent and a decrease in 7-day low flows of almost 30 percent in the Bad River from 1980 – 2009.

## High flow hydrology

Climate change has increased peak flow events. For example, Fitzpatrick et al. (2013) noted a 10% increase in peak flows at the Bad River from 1980 – 2009, likely due to an increase in the intensity of precipitation events. The Chequamegon Bay region experienced the greatest flood on record in July 2016. Over 25 cm of rain fell in one day in some areas of the middle Bad River watershed (Fitzpatrick et al., 2017). Flooding was widespread throughout the region, and the Bad River rose from 300 to 40,000 cfs, its highest recorded discharge (Fitzpatrick et al., 2017). This storm caused more than 38 million dollars in damages to local infrastructure (Cushman, 2019). Flooding occurred again in June of 2018 when 16 cm fell in the Ashland area over 2 days (National Weather Service, 2021). The governor declared a state of emergency due to flooding that caused severe damage to roads, bridges, and culverts (National Weather Service, 2021).

The intensity and duration of large storm events have substantial effects on high-flow hydrology. This can affect in-channel and bluff erosion processes and sediment movement (Peppler, 2006). Blodgett (2009) showed that repeated high-flow events in North Fish Creek, near Ashland, saturated the soils, causing bank and bluff instability, and significant erosion.

Climate change can also affect the seasonality of high-flow events associated with snowmelt. Gebert et al. (2016) showed a decrease in annual peak discharge in the Bad River and suggested it may be due to a shift in the timing of spring snowmelt runoff, which is happening 5-10 days earlier in the Great Lakes Basin over the period 1953 - 2004 (Hodgkins et al., 2007). The shift likely relates to increased air temperatures in February and March reducing the thickness of the snowpack before the spring melt. Gyawali et al. (2015) noted similar seasonal trends in the monthly runoff for the Bad River over a similar time period. Notable increases in the monthly runoff between the periods 1951 - 1980 and 1981 - 2010 were observed for March and October with significantly less runoff in April and May. Fish life cycles are adapted to flow regimes, so changes in flow regimes have important implications for both resident and migratory native fish species including survival and habitat alterations that affect growth (Lytle and Poff, 2004; Poff et al., 2010).

## Effects of land use and land cover on stream hydrology

Historic logging, burning, and conversion to agriculture by European settlers since the 1800s have altered stream hydrology in the basin (e.g., Verry, 1983, Pomeroy et al., 1997). In this section, we describe the relationships among the landscape attributes that affect hydrology in the Lake Superior basin, including the extent and type of forest cover, watershed storage, channel and upland roughness, agriculture and tile drainage, and urban runoff.

### Watershed storage

Watershed storage generally refers to the surface area of wetlands, lakes, and ponds. The USGS identified watershed storage as one of the most significant parameters for predicting peak flows in Wisconsin (Walker and Krug, 2003). This work was updated in 2016 (Walker et al., 2017) with new regression models that included the percent forest in the watershed, but not watershed storage, which was no longer a significant predictor of peak flow. The USGS models for Minnesota (Lake Superior’s north shore watersheds) include only the lake and drainage basin area.

Wetland area has been reduced more than lakes and ponds, due to conversion to other land uses (Walker et al., 2017). Wetlands function like natural sponges, storing either flood waters that overflow riverbanks or surface water that collects in isolated depressions. As flood waters recede, the collected water is released slowly from wetland soils. Wetlands can reduce the severity of downstream flooding and erosion by holding back some of the flood waters and slowing the rate at which water re-enters the stream channel (Vermont DEC, 2022). In watersheds where wetlands have been lost, peak flood discharge may increase by as much as 80 percent (Vermont DEC, 2022). Wetlands within and upstream of urban areas which have a high percentage of impervious land surface are particularly valuable for flood protection (Vermont DEC, 2022).

The effect of wetlands on water storage depends on the amount of runoff from the drainage basin to the wetland, slope, and soil infiltration rates, as well as pre-storm soil moisture and relative saturation (Walker et al., 2017). Johnson et al. (1990) examined relationships between 100-year storm events and watershed storage. Their data indicated that having at least 10% of the watershed area available for water storage is a critical threshold for the reduction of flood flows. They also note that even small decreases in wetland areas when the watershed is near or already below 10% wetland area can increase peak flows. In Minnesota, Verry et al. (1988) observed increases in peak flow with 30% of peatland mire wetlands drained. The amount and intensity of precipitation, antecedent conditions, and location of the peatland within the landscape were relevant to peak flow effects. Peak flows increase exponentially as wetland depression storage decreases below a threshold value of 5–10% watershed area (Jacques and Lorenz, 1988; Krug et al.,1992). Detenbeck et al. (2004) put the figure at 18 – 24% depression storage. Blodgett (2009) estimated a 25 - 40% reduction in peak flows with the installation of a network of dry dams and restored wetlands in the uplands of the North Fish Creek watershed. Blodgett emphasized the importance of considering the cost-effectiveness of measures to reduce peak flow in targeting BMP installation. Wetland storage capacities can also contribute to base flow (Bullock and Acreman, 2003).

Floodplains and riparian wetlands are important elements of a well-functioning watershed. Floodplains are the low-lying areas of land around a river where floodwaters extend when a river or stream exceeds its bank-full channel capacity. The floodplain of a river provides temporary storage for floodwaters and sediment produced in the watershed. The temporary storage serves to slow the downstream impacts of a flood. Floodplain soils absorb water from overfilled riverbanks and slowly release the moisture to floodplain vegetation and back into the stream channel. Streambank vegetation also helps cool surface water temperatures of small streams and supports high plant and animal production and diversity.

In all four Wisconsin counties of the basin, the Land and Water Conservation Department plans’ identify wetland restoration as a priority to reduce peak runoff. A summary of best management practice guidelines for the region recommends “utilizing set aside programs to remove marginal agricultural lands from production and allow wetland characteristics to reestablish in drained areas” (Schultz, 2003). Douglas County utilized a landscape-scale approach to wetland restoration prioritization (Douglas County, 2016). Created with significant stakeholder involvement, this plan “utilizes the best available scientific information to identify watersheds that indicate high vulnerability to increased surface water runoff due to large storm events, recommends actions to reduce this risk, and is consistent with community land-use goals.” Watershed-scale criteria used to identify high-priority sites included watersheds with the most wetland loss (HUC 12 scale) and more than 30 – 40% open land (HUC 14 scale). Site-specific restoration criteria include potentially restorable wetland (PRW) areas on or adjacent to lands transitioning out of agricultural use with hydrologic connection to waterways and proximity to other existing wetlands or public land.

Once priority watersheds are identified, project siting and the amount of additional storage capacity needed must be determined. Emerson (2005) suggested that approaches to peak runoff reduction should focus on volume-based control methods. Hapner (2006) estimated wetland storage as a function of surface area in southeastern Wisconsin and recommended wetlands be designed to retain a volume equivalent to a 1 cm rain event in the watershed of the wetland. Emerson (2003) found that the installation of detention basins for peak flow reduction in random locations did not notably reduce peak flows. However, Giudice et al. (2014) showed that adding detention basins in parallel (along separate “parallel” tributaries) was effective in reducing peak flows and that detention basins added in series (multiple basins along a single tributary) were less efficient in water storage. In Two Harbors, Minnesota, flooding in the Skunk Creek watershed was successfully mitigated using staged release culverts and 3 flood retention basins in the watershed (NOAA, 2019).

Research in incised rivers in southern Minnesota has focused on the potential for water retention to reduce peak flows to reduce erosion of near-channel sediment sources (bluffs and streambanks). There are many ways to hold water back on the landscape, including wetland restoration, in-ditch storage, and installation of control structures in subsurface tile networks. Mitchell (2015) explored the effectiveness of water retention on peak flow reduction using a SWAT (Soil and Water Assessment Tool) model for the Le Sueur watershed in south-central Minnesota. The model showed that water retention could lower peak flows and thus lower near-channel erosion rates (Mitchell et al., 2018). Water retention basins underlain with high hydraulic conductivity soils had a bigger impact than basins with low hydraulic conductivity because the water was able to infiltrate faster between storms (Mitchell et al., 2018). The study also found that water retention basins placed higher in the watershed were more effective than water retention basins closer to the mouth (Mitchell et al., 2018). Later work by Hansen et al. (2021) found that restoring the water retention capacity of floodplain wetlands was even more cost-effective than upland water retention basins at reducing erosion associated with peak flow events. Reductions in peak flow began with the first water retention site installed; no threshold had to be reached before peak flows were reduced (Mitchell et al., 2018). New methods for digitally delineating riparian and floodplain areas using the Height Above Drainage (HAND) technique have been used to map 100 yr flood inundation zones in Texas and North Carolina (Zheng et al., 2018). HAND delineated floodplains and inundation zones compared well with modeled delineations using more complex techniques (HEC-RAS 2D) and show potential for identifying disconnected floodplains (Afshari et al., 2018).

### Upland and in-channel roughness

In-channel and overland roughness conditions can significantly affect watershed hydrology (Borah and Bera, 2003). Fitzpatrick et al., (2015) modeled peak flows as a function of land cover and soil type in the Cranberry River watershed of the Bayfield peninsula. Slope and roughness of both the stream channel and contributing uplands were considered in estimates of runoff volume across different land cover scenarios, including pre-settlement, and conditions during peak agriculture in the early 1900s peak agriculture (1928), late 20^th^ century, and developed conditions (25% urban). Modeled flood peaks were lower in magnitude and greater in duration pre-settlement compared to the late 20^th^ century conditions, largely attributed to higher overland and in-channel roughness during the pre-settlement period.

The watershed position is important for in-channel roughness projects. Pratt and Blust (2005) recommend focusing on in-channel roughness restoration projects in the upper reaches of streams. They found that in-channel structures in the lower reaches of Bayfield Peninsula streams were washed out during storm events or buried with sediment. The evaluation of some in-channel bank stabilization projects established by the RCIC found that the original structures installed were no longer present; however, it appears the structures persisted long enough to allow vegetation to become established (RCIC, 1964, 1977).

The Utah State University Restoration Consortium put together a design manual to provide restoration practitioners guidelines for implementing low-tech tools in wadable stream channels to increase roughness and simulate natural processes (Wheaton et al., 2019). They advocate for using simple, low unit-cost structural additions to riverscapes to mimic natural functions. They focus most of their efforts on promoting large woody debris in streams to influence hydraulic conditions. The large woody debris simulates the impact a beaver dam would have, creating a more complex stream habitat. The impacts of beaver on stream ecosystems have been well documented (Burchsted et al., 2010; Naiman et al., 1988). Their dams influence stream complexity by altering patterns of erosion and deposition. This heterogeneity increases lateral connectivity by promoting overbank flows, which are critical for creating and maintaining floodplain habitats and promoting groundwater recharge (Westbrook et al., 2006); and supports riparian vegetation. They argue that engineering-based methods tend to emphasize channel form and stability, rather than promoting the processes that create and maintain healthy riverscapes, which leads to increased costs and a limited ability to restore more miles of riverscapes.

Gullies can also be substantial areas of accelerated runoff and erosion. Gullies develop from surface water runoff or groundwater sapping. In surface water driven gullies, overland flow leads to the downcutting of steep, v-shaped gullies. In the geologic transition zone area of the basin, quick shallow groundwater flow (similar to piping) in areas with clay sediment overlaying sand can lead to u-shaped gully formation from the base of the drainage upwards, due to the higher erodibility of sand than clay. The type of gully influences the type of management action needed to improve hydrology. Increasing the interception of flow in gullies may be effective in the geologic transition zone area. In areas with more permeable soils, increasing roughness elements to improve infiltration may be appropriate. [Fitzpatrick][WM1] tested rehabilitation techniques to slow flow, reduce erosion, and increase infiltration in gullies of the Bark River watershed. They installed a series of 1- to 1.2 meter-high porous check dams as grade control, filled gullies with large wood pieces, and planted herbaceous native species to stabilize and reduce runoff in steep gullies (Figure 13). Monitoring in 2010 indicated that the technique reduced incision at restoration sites and that the increased roughness slowed runoff.

Figure 12 Roughness elements (anchored wood) installed in upland gullies draining to the Bark River

Photo courtesy of Faith Fitzpatrick.

The Wisconsin Wetland Association (2018) documented how gullying, channel incision, and head cutting have contributed to erosion-induced wetland drainage and floodplain disconnection in Lake Superior watersheds. When fluvial erosion is intensified by changes in land cover or floods, channels can extend upslope into or form in areas that naturally store water. Erosion-induced drainage accelerates surface and sub-surface flows into these channels, lowering the water table, limiting access to floodplains, and causing upstream wetlands to be partially or fully drained. Public infrastructure can be at risk if flows are energized in incised channels, gullies, ravines, and existing wetlands, and if floodplains with limited reduced storage capacities cannot intercept and store water upstream of culverts and bridges (or unstable bluffs).

### Forest cover

In addition to a multitude of benefits to water quality and aquatic ecosystems, forests influence stream hydrology by influencing channel roughness, base flow, snowpack accumulation, snow melt, interception of rain events, and evapotranspiration rates. The age, species composition, and structure of the forest affect the volume and timing of runoff in the channel. Methods to describe forest characteristics and define forest cover vary greatly in the literature, and include forest shading, percent canopy density, canopy closure, and crown coverage (Varhola et al., 2010).

WDNR (2010a) compiled an extensive review of forestry and hydrologic relationships in Wisconsin’s portion of the Lake Superior basin, as part of a comprehensive project to strengthen the implementation of silvicultural best management practices (BMPs) on private and public lands in the area. The major objectives of the project focused on restoring and managing watersheds, streams, riparian areas, and wetlands for water quality protection, with an emphasis on non-point source pollution. Highlights from that work and additional literature are presented here.

#### Forest cover and base flow hydrology

Evidence for a relationship between landscape conditions in the Lake Superior basin and hydrology is mixed. Fitzpatrick et al. (2015) found that base flows in Bayfield peninsula streams are strongly influenced by groundwater recharge in the Northwest Sands area of the central portion of the peninsula. They found that the historic conversion of forest land to agriculture had little effect on groundwater inputs from the deep-water aquifer system. Similarly, Lenz et al. (2003) found that reductions in forest cover in the Whittlesey Creek watershed have little effect on base flow and average flow hydraulic conductivity. Model evaluation by Gerbert (1979) determined that forest cover in the mid to late 1970s was not a significant predictor of base flows in streams of the Lake Superior basin.

Other authors have reported relationships between forest cover and base flow in similar landscapes throughout the region and elsewhere in the country. Detenbeck et al. (2004) studied relationships between watershed conditions and a variety of flow metrics in Minnesota and Wisconsin streams in the Lake Superior basin. They found that reductions in mature forest cover depressed base flow measured as two metrics corrected to median discharge: discharge exceeded 90% of the time (Q_90_) and mean annual minimum daily flow. Flynn (2003) found that forest cover type (deciduous vs. conifer) and summer air temperatures were related to 7-day average minimum flow during 2- and 10-year periods in New Hampshire streams. They presumed that greater interception and storage in conifer-dominated forests reduced base flows by increasing evapotranspiration, thereby reducing infiltration that would otherwise be discharged to streams (Dunne and Leopold, 1978). Nejadhashemi et al. (2012) used SWAT models to examine the effect of land use change at different scales in Wisconsin and Michigan watersheds of Lake Michigan tributaries. They compared pre-settlement, primarily forested conditions, with present-day conditions (nearly 50% of land in crop production, and with less than 20% urbanization). They found that these land uses changes resulted in an increase in evapotranspiration and a decrease in base flow by 50%. This research suggests that forest cover characteristics have a variable effect on baseflow throughout the basin, with a negligible effect in the Northwest Sands region.

#### Forest cover and high-flow hydrology

Forest cover influences high-flow events through its effect on snowpack accumulation (see review in Muss, 2011). In general, the amount of snow accumulation decreases as forest cover increases, as snowfall is intercepted by the canopy and some moisture is returned to the atmosphere via sublimation (Essery et al., 2003). A greater proportion of snowfall will be intercepted by forest canopy in low-intensity snowfall events. Murray and Buttle (2003) summarized findings from over 20 published papers on snow water equivalence (SWE, the amount of water contained in snowpack) in open sites and forest stands in northern hardwoods. SWE was consistently greater in open sites compared to forested sites, with the difference between cover types ranging from 4 to 300%. Most studies showed an increase in SWE of 15 and 60% in open sites over forested sites. In their central Ontario study, Murray and Buttle (2003) found increased snow accumulation and SWE in a cleared section of northern hardwood forest. The variation in SWE was driven by differences in canopy structure, stand age, and stand basal area, as well as snow event characteristics. Canopy closure and plant area index (area of all plant elements per unit ground area) are among the main determinants of snowpack accumulation (Muss, 2011).

The size of clear-cut or open areas also influences snow accumulation. Open sites that are only two to five tree-heights wide accumulate the most snow (Golding and Swanson, 1986, Troendle and Leaf, 1980). These smaller openings are sheltered by surrounding forests and protected from the wind that can redistribute snowpack. In areas with less wind, opening size is less of a factor in determining snow accumulation.

Forest type, age, and spatial arrangement (slope aspect) in a watershed affect the timing of spring snowmelt, and the resulting size and duration of peak or elevated streamflow (Buttle et al., 2005, Verry, 1983). Differences in shading among coniferous forests, deciduous forests, and open lands affect the amount of solar radiation and resulting hydrologic patterns. Muss (2011) studied these relationships in the Bark River watershed in the Bayfield peninsula. He utilized LIDAR data to characterize canopy cover in a 78-hectare subwatershed. He then modeled snowpack and melt in that subwatershed as a function of forest cover type and found substantial differences in peak discharge among the mature evergreen forest, mature broadleaf forest, and treeless cover scenarios, estimated as 12.5, 20.0, and 35.1 liters/second respectively. Total streamflow volume also differed greatly among sites, with treeless landscapes contributing 25% more than broadleaf forests, and 113% more than evergreen forests. His work found that canopy cover had the greatest influence on peak seasonal SWE and snowmelt, while both plant area index and canopy cover influenced the rate of delivery and timing of snowmelt.

Many authors have studied relationships between forest cover and hydrology elsewhere. Pomeroy et al. (1997) found greater infiltration of snowmelt, less surface runoff, and lower peak flows in coniferous forests of southern Saskatchewan compared to cleared areas. Verry (1983) conducted an 18-year paired watershed study of snowmelt and rainfall response to clearcutting in an 84-acre watershed in the Lake Superior basin in northern Minnesota. He found that peak storm flows doubled after clearcutting for three to five years, with elevated peak flows persistent for 9 years. Storm flow volume also doubled after clearcutting, but for only two years. At a watershed scale, he reported a 35% decrease in peak flow following clearcutting half of an 84-acre watershed, which they attributed to desynchronization of snowmelt runoff between cut and uncut areas of the watershed. Murray and Buttle (2003) found that forested and clear-cut sites lost snowpack simultaneously, but cleared sites had greater snowpack and higher melt rates, resulting in an increase in the volume and rate of runoff in the spring. However, aspect had a greater influence on snowmelt than clearcutting, with north-facing slopes having the most variability. They suggest estimating melt rates on south-facing slopes since relationships between tree cover and melt volume and timing were strongest there.

The effect of forest canopy on the fate of precipitation, as throughfall, stemflow, or interception, is relevant for watershed-scale hydrologic investigations. Throughfall is the amount of precipitation that reaches the forest floor. Stemflow is the amount of precipitation that flows down the trunk or stem of trees. Interception represents the amount of precipitation that is captured by the canopy and either absorbed or evaporated back into the atmosphere. Price and Moses (2003) studied precipitation and forest canopy dynamics in a mature red oak-sugar maple forest in southern Ontario. They found that during light rainfall events, 50% or more of precipitation is intercepted. As rainfall amount and intensity increase, a greater percentage of precipitation occurred as throughfall, with maximum amounts measured at 80% for events greater than 10 mm. Stemflow was a minor proportion of precipitation at all studied rain events. The amount of precipitation that reaches the ground can increase by as much as 30% with the removal of the tree canopy. Soil moisture levels can increase with decreasing evapotranspiration from fewer trees (Hibbert, 1969). The type of forest cover also influences the nature of flow events via interception and evapotranspiration. Needleleaf evergreen forests can intercept more of the annual precipitation than broadleaf deciduous forests (18% and 11%, respectively) due to higher surface area (Buttle et al., 2005). Riedel et al. (2005) describe an increase in peak streamflow in the Nemadji River due to a 15% loss in interception capacity with a shift from mature red pine to mature aspen. In general, conifer species use more water per year than deciduous trees, making less water available for runoff (e.g., Calder et al., 2003).

Thresholds for percentage loss of mature forest that results in altered streamflow have been estimated. Verry (1986) observed a slight decrease in peak flows in 1-2 km watersheds in northern Minnesota when clearcutting increased from 0 to 40% of the watershed, which he attributed to a staggering of snowmelt that also extends runoff duration. Bankfull flows, generally considered to occur at 1.5 to 2-year recurrence intervals in the region of interest, are described by Verry (2001) as “an index of the range of flows that shape the channel and build the valley floodplain over time.” A doubling or tripling of bankfull flows (and concurrent increases in bankfull velocity and channel slope) occurred at a threshold of greater than 60% open lands, including young forest ≤16 years. Peak flow discharges were not found to be significantly higher below the threshold of 60% open lands (Figure 13). Further, when clear-cuts and open land cover in subwatershed scale units were below the 50% threshold, peak discharges were reduced by 20% due to the desynchronization of flows (Verry, 2005). Detenbeck et al. (2004) modeled peak flow response to a fraction of mature forest (defined as greater than 15 years in age) in second and third-order streams in Wisconsin’s Lake Superior basin and found that above a threshold of 51 to 64% open lands, peak flows increased. Model results from Lenz et al. (2003) found that complete reforestation of the Whittlesey Creek watershed would reduce flood peaks by 12 to 14% for a 100-year event. The rate of land clearing and forest regrowth can also influence bankfull flows since recently cut forests have higher runoff rates compared to a mature forest (Lenz et al., 2003). Verry (2005) found that forest harvest rates greater than 1½% watershed area per year increased bankfull flows that adjusted the channel.

To promote open land species like sharp-tailed grouse in the agricultural areas of Ashland, Bayfield, and Douglas counties, Schultz (2003) recommends maintaining 15 to 30% open grass and brushlands. This recommendation is generally consistent with the hydrologic recommendation of maintaining open lands below 60% of the subwatershed area. However, sharp-tail grouse conservation efforts in areas that are already close to or above the 60% threshold due to the presence of urban or agricultural land use may be at odds with hydrologic targets.

Figure 13 Relationship between the amount of open land in a subwatershed to change in peak flow (Verry, 2001)

Blue lines define the range of variation in response to open land or young forest based on empirical measurements (symbols).

#### Riparian buffers

Riparian buffers can play an important role in stream hydrology. Wisconsin Forestry BMPs for Water Quality (2010) describe Riparian Management Zones (RMZ) as “areas next to lakes and streams, where forest management practices are modified to protect water quality, fish habitat, and other aquatic resources.” RMZs have value for wildlife habitat, are a source of habitat-creating wood to streams, and help moderate stream temperatures. They are also critical in helping to minimize the effects of non-point source pollution (e.g., sediment, nutrients) on surface waters. In addition to these benefits, riparian buffer zones with forest cover can slow upland runoff and promote greater soil infiltration (WDNR, 2011).

However, the effectiveness of riparian buffers can be overwhelmed if direct drainage pathways to stream channels develop from roads or skid trails, gullies, or other concentrated flow areas (Dosskey et al., 2002). Equipment operations that compact soils in riparian areas can limit soil infiltration within riparian buffers (Hamza and Anderson, 2005). Reach-scale differences in soil type, topography, stream size, geology, and watershed size influence the size and shape of functional riparian zones. Site scale conditions and vegetation type also influence buffer effectiveness (Dosskey et al., 2002).

#### Additional considerations

Potential changes to forest stands outside of management prescriptions, like invasive species and climate change, are also important. The presence of emerald ash borer (EAB) has been confirmed in the study area in the City of Superior and Iron County (Oma, WI). to the east. Although the infestation is slow-moving, when the EAB attacks a tree, it is nearly 100% fatal. Ash trees make up a substantial portion of riparian areas along some stream reaches. Losing these trees to the EAB could have significant effects on hydrologic function and stream habitat, although effects are still poorly understood (e.g., Larson, 2020). Slesak et al. (2014) conducted experiments simulating EAB infestation and found the experimental plots had similar impacts on the water table as recent clear-cutting. Impacts on the water table were more pronounced when the water table was within 30 cm of the soil surface (Slesak et al., 2014).

Climate change may result in changes to forested habitats due to forest damage from wind events. Initial estimates from the U.S. Forest Service are that over 3,000 acres of forest land in the central Bayfield region were damaged during a high wind event in June of 2016. Private forest lands were certainly affected by this event as well. This event increased the proportion of open lands in this concentrated area.

Janowiak et al. (2014) provide an extensive review of additional potential impacts of climate change on forest resources including range and distribution projections for specific forest communities. Overall, they predict a reduction in boreal species, negative impacts on lowland conifers, and potential expansions of more southern species such as black cherry, northern red oak, and red maple. It is unclear yet how these projected changes will affect stream flow.

### Agricultural lands

While forested lands are the dominant land use in the Lake Superior basin, agriculture is another important land use. Practices on agricultural land and their effects on watershed hydrology in the Lake Superior Basin fall into three main categories: conversion of forest to agricultural lands, ditching and drain tiling, and implementation of BMPs to protect water quality. Land conversion and drainage have the greatest effect on hydrology in the Lake Superior Basin. Agricultural BMPs primarily address what is in runoff rather than the volume or rate of runoff; however, some practices can be effective in reducing overland runoff volumes and rates.

#### Conversion of forest to agriculture

Many researchers have used modeling approaches to examine the effects of forest conversion to agriculture on stream hydrology. Fitzpatrick et al. (1999) found that increased agricultural activity in North Fish Creek increased the peak flow of above-bankfull events for the mid and upper reaches of the watershed, but not the lower reaches. Two-year peak discharge tripled during years of peak agriculture (Fitzpatrick et al., 1999). The conversion of coniferous forest cover to agriculture increased peak flows in the Nemadji River watershed as well (Riedel et al., 2001, Riedel et al., 2005). Model results indicated that a return to row crop agriculture to 1920 levels in the Whittlesey Creek watershed would increase flood peaks by as much as 18% (Lenz et al., 2003).

Since the forest cutover and the peak of agricultural land use in the 1920s, the region has seen significant conversion back to forestland with minimal forest conversion to agriculture since then. However, since 2010 there has been some new forest clearing for agriculture, particularly in the Marengo Valley of Ashland County where the remaining dairy farms are expanding. WICCI models forecast an increase in the growing season and northern shift in plant hardiness zones that, combined with market forces, could potentially expand agricultural opportunities in the northern part of the state (WICCI, 2011).

#### Ditching and drain tiling

The low topographic relief clay soils of the Lake Superior Basin are almost impossible to farm without some form of engineered drainage like ditches, concentrated flow channels, or drain tile. Figure 14 shows a typical field in the Benoit area of Bayfield County with a network of maintained concentrated flow areas. Best management practices and regulations require producers to maintain these drainages in perennial vegetation to reduce runoff and erosion. However, 58% of runoff occurs between January 1st and March 31, when the flow channels are frozen and vegetation is flattened (Cooley, 2015). Stuntebeck et al. (2011) investigated runoff and constituent concentrations from 23 fields ranging in size from 2- to 75-acre subwatersheds from 2003 to 2008. They note that practices that rely on living vegetation are not effective during frozen ground conditions in late winter when a large portion of runoff occurred. While best management practices for maintaining the flow channels in perennial herbaceous vegetation have only a limited impact on reducing peak flow, they do provide other ecological benefits including wildlife habitat.

Figure 14 Typical agricultural field in Bayfield County with extensive surface drainage

Image courtesy of Jason Fischbach.

Ditching to re-route and concentrate landscape-derived runoff is ubiquitous throughout the Lake Superior basin. Ditches were created to drain wetlands in the low-relief red clay plain portion of the basin. Accelerated field drainage into ditch networks provides earlier access in the spring for tilling and planting. Verry (1988) notes that bankfull flows double when ditched agricultural lands or wetlands exceed one-third of a basin. The Nemadji Basin Plan states that while as much as 50% of agricultural lands in the Nemadji basin have been converted back to forest cover, substantial numbers of surface ditches installed on historic farm fields lands still drain the landscape today (Cooper and Lensch, 1998). Removing these relict ditches could represent a significant opportunity, especially in the Nemadji Basin but likely throughout the Lake Superior basin, to slow the flow of runoff to streams through the re-establishment of wetlands on currently drained land, with minimal effort and cost.

Although historically not extensively used in the Lake Superior basin, agricultural producers in the region have begun installing drain tiles. As competition for land increases, producers will likely find it more cost-effective to drain wet areas on their existing fields rather than purchase additional land. These subsurface drains remove water from fields at a fast rate in the spring and during prolonged saturation periods and respond quickly and effectively to rain events (Lam et al., 2016). The rate of drainage from fields in tile drains is a function of drain depth, spacing, size, arrangement, and management (Lewandowski et al., 2015).

#### Agricultural best management practices (BMPs)

There are many conservation practices available that can be applied in agricultural settings. Implementation of BMPs on farmland has been shown to increase fish abundance and improve fish habitat in lakes and rivers downstream (Wang et al., 2002). BMPs that reduce peak stream flows are largely intended to reduce overland flow and increase infiltration infield or at field edges. These practices are well summarized in Lewandowski et al. (2015) including a description of the practices and the mechanisms by which hydrology is influenced (Table 1). They emphasize the importance of implementing a suite of practices throughout a drainage network or farm operation to effectively influence stream flow. The specific types of BMPs and the extent to which they can be applied in any given location vary depending on the type of farming and local conditions. Highlights from Lewandowski et al. (2015) and additional literature are presented here to describe relationships between individual agricultural BMPs and their effects on hydrology.

#### Grassed waterways and two-stage ditches

Grassed waterways (GWWs) are common in the Lake Superior basin (Figure 15). These constructed and graded drainage ditches are planted with grasses and used to convey water off fields while slowing runoff and increasing infiltration rates. The effectiveness of GWWs is determined by the inflow rate, vegetation characteristics, channel cross-section, and channel length. Fiener and Auerswald (2003, 2005) compared the performance of unmanaged and managed (cut annually in August) GWWs. Damaging sedimentation in the GWW can be reduced by frequent mowing, but this process decreases the effectiveness of the GWW secondary functions such as the ability to retain sediments and reduce runoff volume. Annual mowing encouraged fast-growing grasses and significantly improved the performance of the waterway in slowing runoff during the growing season. They also found that flat-bottomed GWWs with stiff grasses and herbs at least 0.15 meters tall reduced runoff volume and peak discharge rates. Kalantari et al. (2014) reported a 28% decrease in peak flows associated with GWWs in silty clay soils during 50-year storm events in a 4.5 km^2^ watershed. The width of a GWW can influence performance. A narrow GWW can be effective in preventing gully erosion; wider GWWs have added benefits of surface water runoff reduction. Mowing GWWs reduces overland roughness, and limits reductions in surface runoff rates. The RCIC (1977) tested grassed waterways and ditches extensively. They found GWWs to be very effective in reducing sediment delivery associated with increased runoff and noted the importance of preventing grazing in GWWs to ensure their effectiveness.

GWWs are typically 3 meters wide, consistent with bulldozer and scraper blade widths. Grassed waterways are challenging to maintain, especially when growing annual row crops that require regular crossing with farm machinery, which can create ruts and compact soils, reducing infiltration rates and impairing the function of a GWW to reduce runoff. GWWs are easier to maintain effectively with perennial forages.

Figure 15 Example of a grassed waterway

Photo courtesy of the NRCS.

Two-stage ditches are designed with elevated benches along each side (Figure 16, Powell et al., 2007). Two-stage ditches mimic a natural channel; the benches serve as a floodplain for the ditch. During low flow periods, they function as wetlands and absorb nutrient loads, and during high flow periods, they allow flow to spread out and slow, increasing ditch stability and reducing erosion and peak flows (Mahl, 2015). Two-stage ditches also improve in-field wildlife habitat compared to traditional ditches (DeZiel, 2019), and are also maintained with grass.

In Wisconsin’s Lake Superior basin, the heavy clay soils require extensive ditching to adequately dry fields for planting in the spring. Installing grassed waterways or two-staged ditches on all ditches that drain fields would leave little room for production. As a result, when they exist, they are usually installed only on major or mainstem ditches.

Figure 16 Schematic of a two-stage ditch (After Powell et al., 2007)

#### Vegetative filter strips

Vegetative filter strips (VFS) are typically installed to slow surface runoff within or from fields, thereby reducing or minimizing sedimentation or nutrient water quality degradation. The design width and arrangement of VFS varies based on site-specific conditions, including consideration of drainage area, contamination source areas, slope, and proximity to environmentally sensitive areas (NRCS, 2014). VFS are frequently installed on the contour within fields or at field edges to reduce runoff and promote infiltration. Seeding criteria for VFS are identified in NRCS Practice Standard 393 and include consideration of locally appropriate species selection, soil saturation, and proximity to waterways. VFS are most effective when sheet flow, rather than channelized flow occurs. To function as intended, filter strip maintenance includes redistribution of accumulated sediments, maintaining vegetative cover, and limiting heavy equipment operation within the VFS. Veum et al. (2009) investigated the effect of VFS width on performance in the clay pan region of Missouri and found that VFS that were 4.5 meters in width, comprising 8 to 10% of the field, reduced runoff by 8.4%.

#### Riparian Buffer Strips

Riparian buffer strips (RBS, also known as conservation buffer strips) provide a corridor of vegetation around waterways and function much like a filter strip along field edges where sheet flow is predominant. Chase et al. (2016) showed that a less than 20% increase in riparian forest cover relative to agricultural intensity reduced the severity of summer low flow periods and improved water quality. Sheridan et al. (1999) evaluated the effectiveness of RBS consistent with NRCS specifications (a three-zone system extending from the stream edge upland that includes no harvest, some forest harvest, and grass filter management zones). They found significant reductions in runoff and sediment transport utilizing this system, even with harvest in the intermediate forest zone. However, the development of concentrated flow areas within riparian areas allows surface runoff to bypass buffer zones, limiting the effectiveness. Flow concentration can be extensive in riparian buffer strips, likely leading to their varied infiltration efficiency from 9% to 100% (Helmers et al., 2006). Pankau et al. (2012) found that 82 to 100% of drainage leaving farm fields occurred in concentrated flow areas, with greater occurrence in agricultural rather than in forested watersheds of southern Illinois. Concentrated flow areas that direct runoff through the buffer strip are common in the Lake Superior basin as well (Jason Fischbach, personal observation). As part of their watershed-scale wetlands management plan, Douglas County (2016) utilized aerial photo interpretation to identify evidence of channelization, quantify with woody riparian vegetation density, land use, and amount of grazing in the riparian zone to identify potentially restorable stream/riparian areas. Dosskey et al. (2002) recommend combining field observations of runoff pathways through VBS with model estimates of pathway dimensions to estimate buffer effectiveness. This provides an improved estimate of buffer value in reducing runoff and can guide restoration actions at a local scale.

#### Conservation tillage

No-till practices increase the amount of organic matter at the soil surface and have been shown to slow the amount of runoff on non-frozen soils, allowing for infiltration in fields (Discovery Farm, no date). Potter (1991) suggests that the increase in soil roughness associated with conservation tillage likely decreases spring runoff volumes and increases baseflow. Bro and Fratt (2011) recommend conservation tillage as an important agricultural practice for the Fish Creek watershed to reduce surface runoff.

The extent and severity of soil compaction in the Lake Superior Basin are unknown, but with the heavy clay soils and the necessity and/or the tendency of farmers to operate in wet fields, compaction is assumed to be severe and widespread. Breaking up the plow pan layer associated with moldboard plowing, would likely increase infiltration rates, and reduce the volume of runoff (Cooperative Extension Service, 1994). In high clay content soils, tillage is typically required to alleviate soil compaction. Compaction can be reduced through strip tillage and in-row subsoiling or paratilling (Naderman et al., 2006; Raper et al., 2005; Raper et al., 2007). Paratilling is a deep tillage technique in which the soil is loosened below the soil surface but not inverted (Langdale et al., 1990). Compaction can also be alleviated by certain deep-rooting cover crops, including cereal grains and radishes (Anguelov, 2020). These techniques are useful to reduce compaction while reducing the risk of erosion due to tillage.

#### Perennial crops/cover crops vs annual row crops

Efforts to perennialize the Midwestern agricultural landscape have existed since the 1930s when the extent and severity of soil erosion became evident. Recently, the Green Lands, Blue Waters Initiative in the Upper Mississippi River basin (www.greenlandsbluewaters.org) has been working to integrate the concept of continuous living cover into agricultural policy and production. Continuous living cover could include the use of cover crops in annual row crop systems, perennial forage crops, or new perennial grain and biomass crops. The objective is to have roots in the soil and vegetation on the surface 365 days a year. Perennial crops have better infiltration rates and greater surface roughness to slow runoff in addition to habitat benefits.

With 87% of the agricultural lands in the Lake Superior Basin currently in perennial forages, any conversion to annual row crops is likely to increase the impact of agricultural lands on runoff peak flows. This is particularly true for row crops harvested late in the season, such as corn. With such a short season, farmers in the basin must wait as long as possible in the fall for the corn to ripen and dry before harvest. Often, the fields are wet late in the fall due to lower temperatures and less evapotranspiration.

The corn must get harvested, despite the wet soils, and the result is significant surface compaction. This compaction persists throughout winter months resulting in significant surface runoff, particularly in the spring.

#### Short rotation woody crops (SRWC)

The production of short-rotation woody crops for bioenergy or pulp has been an area of active research in recent years. Cottonwood and willow species, including hybrids developed for rapid growth, extensive root systems, and hydraulic control potential, can be planted and harvested in cycles of less than 20 years, depending on the crop product (Zalesny et al., 2019). Bioenergy crops can be harvested on a 3–5 year rotation; pulp crops can be on a 10-12 year rotation or up to 20 years for saw timber. The trees grow back from the stump, so re-seeding or planting is not required, and soil disturbance is limited to harvest. Although Verry (1983) defined forest lands under 15 years of age as open land in his open lands definition, research by Perry et al. (2001) found that SRWCs do not perform similarly to open lands. They suggest that SRWC could reduce peak flows from both rainfall and snowmelt events because of the desynchronization of runoff.

SRWCs tend to have faster growth rates than native forest cover (Miller and Bender, 2008). Thus, the dominant trees in a 10-year-old hybrid poplar planting, for example, may be equivalent to a 20 to 30-year-old native aspen stand. That said, the first two years during the establishment of the SRWC plantings phase requires a weed-free condition that may contribute to a temporary increase in run-off and erosion. Even so, the impact of SRWCs should be evaluated in comparison to traditional agricultural crops rather than mature native forest cover, as SRWCs are more likely to be planted in agricultural fields rather than as a component of reforestation.

Figure 17 A coppiced hybrid poplar stand (background) with more spring snow retention than an uncoppiced mature hybrid poplar stand (foreground)

Photo courtesy of Jason Fischbach.

Figure 18 A willow snow fence with spring snow retention

Photo courtesy of Jason Fischbach.

#### Cumulative effect of multiple best management practices

Research on the cumulative effect of BMPS on hydrology is limited by a lack of consistent data on practices utilized at a watershed scale. Potter (1991) evaluated changes in agricultural operations from 1940 to 1986 in the steep terrain and moderately drained soils of the Driftless area in southern Wisconsin. He notes that 83% of farmers in the study watersheds were involved in some conservation program with a variety of practices employed, but the type, extent, and location of specific practices were not available for their study. He found that both the peak and volume of winter/spring stream flow events decreased over the period of record independent of climate changes.

Inamdar et al. (2001) investigated the effects of strip cropping, conservation tillage, and nutrient management BMPs on hydrology and nutrient runoff in two Atlantic coastal plain watersheds. They found a significant increase in average streamflow between pre- and post-BMP periods, which they attributed to increases in baseflow. Corresponding significant decreases were also observed in nutrient concentrations and loads.

Other authors debate the effectiveness of agricultural BMPs on influencing hydrology, with some stating that precipitation changes influence streamflow more than land use (Gupta et al., 2016), and others showing that agricultural practices significantly increase runoff and concurrent streamflow (Schottler et al., 2016), particularly by reducing base flow (Schilling, 2016). Cho et al. (2019) examined the effectiveness of different management options to reduce sediment loading in the Le Sueur watershed, a large agricultural watershed in south-central Minnesota. They compared water retention to other sediment management practices including conservation tillage techniques, grassed waterways, buffers, ravine stabilization, and bluff stabilization. They found that the most cost-effective way to reduce sediment loading was through a combination of ravine head cut stabilization, bluff stabilization, and water retention in the upper basin. Water retention had the greatest potential in terms of the total mass of sediment removed; a >70% reduction of the initial fine sediment load was achievable with water retention alone.

Consideration of potential changes in temperature and precipitation due to climate change should influence strategic approaches to hydrologic restoration. In addition to the potential for expanded agricultural opportunities in the basin due to lengthened growing seasons and shifts in plant hardiness zones, the WICCI also notes that an increase in freeze/thaw events could increase soil tilth and infiltration (WICCI, 2011). However, these conditions may be overwhelmed by the increased intensity of rainstorms and higher runoff rates.

### Urban and rural residential

Although constituting a relatively small surface area of most rural watersheds, urban areas can exert considerable influence on local hydrology. Impervious surfaces, much more extensive in developed areas, have smooth surfaces and allow no infiltration, resulting in greatly accelerating runoff. Accelerated runoff from urban areas can increase storm flows, decrease base flows, erode and incise stream channels, and create wider floodplains (WDNR, 1994). Increases in impervious surfaces can increase runoff volume, peak discharge in downstream rivers, runoff velocity, and flooding volume (MPCA, 2016).

The WISCLAND2 dataset displays the extent of urban and rural residential lands throughout the state of Wisconsin, classified as high or low intensity development (WDNR, 2019). High-intensity developed lands are areas with 50% or greater solid impervious cover. Low-intensity developed lands are areas with 25% to 50% solid impervious cover and may have some vegetation. The amount of high and low-intensity developed lands represent a small portion (<2%) of the entire Lake Superior Basin and are dominated by the cities of Ashland and Superior, located in the lower portions of watersheds (Figure 19).

Figure 19 Distribution of developed and protected lands in Wisconsin’s Lake Superior basin, based on the Protected Areas Database (PAD, Gergley and McKerrow, 2016)

PAD is the official inventory of protected open space in the US. It includes lands held in trust by national, state, and some local governments and nonprofit conservation organizations. It includes fee-protected public parks and other lands, designated areas, conservation easements, and Marine Protected Areas. Note that the American Indian Lands include the Red Cliff Reservation at the north end of the Bayfield Peninsula and the Bad River Reservation east of Chequamegon Bay.

Stormwater management regulations of urban/residential areas exist at multiple jurisdictional levels. City and village governments are delegated authority from the State to administer erosion control programs for one to two dwelling construction projects. Permits issued by city or village governments generally address the placement of new structures with respect to property lines and waterways. By limiting the amount of impervious surface near waterways, these permits can help promote riparian buffers that promote infiltration and reduce accelerated runoff to streams. Counties can also develop ordinances that work to protect waterways by reducing the amount and rate of runoff.

Regulation of stormwater statewide is authorized by Chapter NR 216 of Wisconsin’s Administrative Code. Construction projects involving one or more acres of land are required to include site-specific erosion control and stormwater management plans. Erosion control plans address sediment and erosion control during the construction period, and stormwater management plans specify the long-term management of runoff. Some light and heavy industrial activities are required to include a facility-specific stormwater pollution prevention plan, which identifies runoff management, spill response, and routine housekeeping practices. Larger communities (those typically with populations greater than 10,000) are subject to municipal stormwater permits, which require the development of local erosion control & stormwater ordinances, education, and outreach efforts concerning stormwater awareness, and community-wide treatment of urban runoff.

There are a variety of structures that can hold and store surface runoff from urban areas to increase infiltration and roughness. These approaches to mitigate the effects of urban lands on hydrology are well summarized at http://www.stormwatercenter.net/. These structures differ in the volume of runoff they can hold, and the way stored runoff is released from the structure. Wet detention ponds contain a single standing pool of water that is typically 1 to 2.5 meters deep. Water is released at a confined outlet. Infiltration basins can hold similar amounts of water, but stored water is released through the infiltration of the bottom and sides of the basin. Constructed wetlands are another type of water storage structure in urban settings that retain runoff and slowly release it via infiltration. All these practices are effective at storing water and trapping sediment but require ongoing maintenance. The appropriate structure to use depends on the soils, slope, geology, and hydrogeology of a given site (WDNR, 1994).

Built landscaping features that can be used to store overland runoff include rain gardens and other bioretention areas. These are typically used at smaller sites like areas adjacent to parking lots (Figure 20). Surface runoff is directed into depressions that hold water and allow infiltration. These structures can help store water during light rain events but can become quickly overwhelmed during heavier rains. Other urban stormwater management techniques not utilized extensively in Wisconsin’s Lake Superior basin include green roofs, onsite water reuse, and porous pavement.

Figure 20 A newly-installed rain garden in Ashland stores runoff after a heavy rain event

Ditching associated with road networks can lead to accelerated runoff and increased peak flow (Jones and Grant, 1996; Wemple et al., 1996). This is especially true with poorly installed and maintained ditches and culverts. When hydrologically connected to streams, roadside ditches essentially act as an extended stream network. This increases drainage density and consequently water delivery efficiency to streams, particularly during high runoff events (Figure 21). Water delivery from roadside ditches to stream channels, usually where the road crosses a stream channel, can affect the volume and timing of streamflow. At the watershed scale, road ditches have been found to increase the magnitude of mean floods by 2 to 12% and to increase peak discharge by 3 to over 300% (Buchanan et al., 2013). Effects on hydrology may be greater in watersheds where the area contributing to ditch drainage is greater than the area of stream drainage. Harr et al. (1975) found that road systems with an area that exceeds 15% of a watershed will increase streamflow. In addition, road ditches can also convert subsurface drainage to surface runoff (Wemple et al., 1996).

Figure 21 Roadside ditch during spring thaw carrying sediment-laden runoff to a stream or lake

Photo courtesy of Michele Wheeler.

## Appendix 2 References

Afshari, Shahab, Ahmad A. Tavakoly, Mohammad Adnan Rajib, Xing Zheng, Michael L. Follum, Ehsan Omranian, Balázs M. Fekete. 2018. Comparison of new generation low-complexity flood inundation mapping tools with a hydrodynamic model, Journal of Hydrology 556. 539–556.
Anguelov, George. “Conservation Tillage Trade-Offs.” Sustainable Agriculture Research & Education (SARE), SARE, 21 Oct. 2020, https://www.sare.org/publications/conservation-tillage-systems-in-the-southeast/chapter-14-water-management/conservation-tillage-trade-offs/.
Ashland County Land Conservation Committee and Department. 2010. Land and water resource management plan for Ashland County, WI. For implementation 2020 – 2029. 118 pp. Accessed 06.15.2022. https://co.ashland.wi.us/vertical/sites/%7B215E4EAC-21AA-4D0B-8377-85A847C0D0ED%7D/uploads/Ashland_LWRM_Plan_2020_FINAL(1).pdf
Bayfield County Land Conservation Committee and Land and Water Conservation Department. 2010. Land and water resource management plan for Bayfield County, WI. For implementation 2010 – 2020. 58 pp. Accessed 06.15.2022. https://www.bayfieldcounty.wi.gov/DocumentCenter/View/1058/LWRMP-full?bidId=
Blodgett, D. 2009. Modeling flood flow reduction for bluff erosion mitigation using upland runoff attenuation on North Fish Creek, Bayfield County, WI. A best management practice implementation location prioritization. Master’s Thesis University of Wisconsin – Madison. 108 pp.
Borah, D. K. and M. Bera. 2003. Watershed-scale hydrologic and nonpoint-source pollution models: Review of mathematical bases. Transactions of the American Society of Agricultural Engineers 46. p. 1553–1566.
Breckenridge, A. 2013. An Analysis of the late glacial lake levels within the western Lake Superior basin based on digital elevation models. Quaternary Research 80. 383–395.
Bro, K. and T. Fratt. 2011. Fish Creek watershed restoration and management plan. Ashland County Land and Water Conservation Department, Ashland, WI. 84 pp.
Buchanan, B. P., K. Falbo, R. L. Schneider, Z. M. Easton, and M. T. Walter. 2013. Hydrological impact of roadside ditches in an agricultural watershed in Central New York: implications for non-point source pollutant transport. Journal of Hydrological Processes 27. 2422–2437.
Bullock, A. and M. Acreman. 2003. The role of wetlands in the hydrologic cycle. Hydrology and Earth System Sciences 7. 358–389.
Burchsted, D., M. Daniels, R. M. Thorson. 2010. The River Discontinuum: Applying Beaver Modifications to Baseline Conditions for Restoration of Forested Headwaters. BioScience 60. 908–922.
Buttle, J.M., I. F. Creed, and R. D. Moore. 2005. Advances in Canadian forest hydrology, 1999-2003. Hydrological Processes 19. 169–200.
Calder, I.R., Reid, I., Nisbet, T.R. and Green, J.C. 2003. Impact of lowland forests in England on water resources: Application of the Hydrological Land Use Change (HYLUC) model. Water Resources Research 39.
Cannon, W.F., L.G. Woodruff, S.W. Nicholson, C.A. Hedgman, and R.D. Barber-Delach. 1999. Bedrock geologic map of the Ashland and the northern part of the Ironwood 30’× 60’ quadrangles, Wisconsin and Michigan. No. 99-546. The Survey. http://pubs.usgs.gov/of/1999/of99-546/
Carney, S. J. 1996. Paleohydrology of the western outlets of glacial Lake Duluth. Master’s degree Thesis. University of Minnesota, Duluth, MN. 129 pp.
Chase, J.W., G. A. Benoy, S. W. R. Hann and J.M. Culp. 2016. Small differences in riparian vegetation significantly reduce land use impacts on stream flow and water quality in small agricultural watersheds. Journal of Soil and Water Conservation 71. 194–205.
Cho, S.J., Wilcock, P.R., Belmont, P., Gran, K.B. and Hobbs, B.F. 2019. Simulation model for collaborative decision making on sediment source reduction in an intensively managed watershed. Water Resources Research 55. 1544–1564.
Clayton, L. 1984. Pleistocene geology of the Superior region, Wisconsin: Wisconsin Geological and Natural History Survey Information Circular 46, 40 p., 1 plate, scale 1:250,000.
Cooley, Eric. 2015. UW Discovery Farms: Understanding Nutrient and Sediment Loss from Agricultural Landscapes. Presentation to the Bayfield County Large-Scale Livestock Study Committee, May 28, 2015.
Cooper, P., and B. Lensch. 1998. Erosion and sedimentation in the Nemadji River Basin: Final Report, Nemadji River Basin project. Natural Resources Conservation Service, US Forest Service, District Conservationist, Ashland, Wisconsin, 149 pp.
Croley, T., and C. Luukkonen. 2003. Potential Effects of Climate Change on Ground Water in Lansing Michigan. Journal of the American Water Resources Association. 39. 149–163
Cushman, Will. 2019. “Washed Away: Northwest Wisconsin Copes with the Costs of a Changing Climate.” St. Croix 360, 4 Oct. 2019. Accessed 6.15.2022. https://www.stcroix360.com/2019/10/washed-away-northwest-wisconsin-copes-with-the-costs-of-a-changing-climate/
Danziger, Edmund Jefferson. The Chippewas of Lake Superior. 1979; reprint, Norman: University of Oklahoma Press, 1990.
Detenbeck, N.E., V.J. Brady, D.L. Taylor, V.M. Snarski, and S.L. Batterman. 2004. Relationship of stream flow regime in the western Lake Superior basin to watershed type characteristics. Journal of Hydrology 309. 258–276.
DeZiel, B., Krider, L., Hansen, B., Magner, J., Wilson, B., Kramer, G. and Nieber, J., 2019. Habitat Improvements and Fish Community Response Associated with an Agricultural Two-Stage Ditch in Mower County, Minnesota. JAWRA Journal of the American Water Resources Association 55. 154–188.
Discovery Farm. No date. Tillage (or not) and water quality. Discovery Farms Wisconsin. Accessed 3.18.2022 https://uwdiscoveryfarms.org/articles/tillage-or-not-and-water-quality
Dosskey, M.G., M.J. Helmers, D.E. Eisenhauer, T.G. Franti and K.D. Hoagland. 2002. Assessment of concentrated flow through riparian buffers. Journal of Soil and Water Conservation 57. 336–343.
Douglas County Land Conservation Committee and Land and Water Conservation Department. 2009. Land and water resource management plan For Douglas County, WI. For implementation 2010 – 2020. 58 pp. Accessed 6.15.2022. http://www.douglascountywi.org/DocumentCenter/Home/View/357
Douglas County Land Conservation Committee and Land and Water Conservation Department. 2016. A watershed approach to wetland management in the Lake Superior Basin plan. Accessed 6.15.2022. https://www.douglascountywi.org/DocumentCenter/View/8288/Final-LS-Watershed-based-Plan-5_9_16?bidId=
Dunne, T., and Leopold, L.B., 1978. Water in environmental planning. New York, W.H. Freeman and Company, 818 pp.
Eaton, J.G. and R. Scheller. 1996. Effects of climate warming on fish thermal habitat in streams of the United States. Limnology and Oceanography 41. 1109–1115.
Emerson, C. H. 2003. Evaluation of the additive effects of stormwater detention basins at the watershed scale. Master’s degree thesis, Department of Civil, Architectural, and Environmental Engineering, Drexel Univ., Philadelphia. 116 pp.
Emerson, C.H., C. Welty, and R. Traver. 2005. Watershed-scale evaluation of a system of storm water detention basins. Journal of Hydrologic Engineering 10. 237–242.
Essery, R.L., P. Bunting, J. Hardy, T. Link, D. Marks, R. Melloh, J. Pomeroy, A. Rowlands, and N. Rutter. 2008. Radiative transfer modeling of a coniferous canopy characterized by airborne remote sensing. J. Hydrometeorology 9. 228–241.
Farrand, W. R. 1969. The quaternary history of Lake Superior. In Proceedings of the 12th Conference of Great Lakes Research: 181–197.
Fiener, P. and K. Auerswald. 2003. Effectiveness of grassed waterways in reducing runoff and sediment delivery from agricultural watersheds. Journal of Environmental Quality 32. 927–936.12809293
Fiener, P. and K. Auerswald. 2005. Measurement and modeling of concentrated runoff in grassed waterways. Journal of Hydrology 301. 198–215.
Fitzpatrick, F. A., J. C. Knox, and H. E. Whitman. 1999. Effects of historical land cover changes on flooding and sedimentation, North Fish Creek, Wisconsin. U.S. Geological Survey, Water Resources Division Publication. Water Resources Investigation Report No. 99–4083. Middleton, WI.
Fitzpatrick, F.A., M. C. Peppler, H. E. Schwar, J. A. Hoopes, and M. W. Diebel. 2005. Monitoring channel morphology and bluff erosion at two installations of flow-deflecting vanes, North Fish Creek, Wisconsin, 2000–03. U.S. Geological Survey Scientific Investigations Report 2004–5272. 34 pp.
Fitzpatrick, F., M. Fedora, S. Cherwaty-Pergentile, J. Elias, R. Dudley, and G. Hodgkins, G. 2013. Trends in Lake Superior tributary flows. Presentation at the Lake Superior Coordinated Science and Monitoring Initiative workshop, Duluth, MN, September 2013.
Fitzpatrick, F.A., M.C. Peppler, D. A. Saad, D. M. Pratt, and B. N. Lenz. 2015. Geomorphic, flood, and groundwater-flow characteristics of Bayfield Peninsula streams, Wisconsin, and implications for brook-trout habitat: U.S. Geological Survey Scientific Investigations Report 2014–5007, 80 pp.
Fitzpatrick, F.A., Dantoin, E.D., Tillison, N., Watson, K.M., Waschbusch, R.J. and Blount, J.D. 2017. Flood of July 2016 in northern Wisconsin and the Bad River Reservation (No. 2017-5029). US Geological Survey.
Flynn, R.H. 2003. Development of regression equations to estimate flow durations and low-flow-frequency statistics in New Hampshire streams: U.S. Geological Survey Water Resources Investigations Report WRIR 02-4298, 66 pp.
Gerbert, W. A. 1979. Low-flow characteristics of streams in the Lake Superior Basin, Wisconsin. U. S. Geological Survey Water Resources Investigations Open-File Report 79-38. Prepared in cooperation with the Wisconsin Department of Natural Resources. 74 pp.
Gebert, W.A., J. F. Walker, and J. L Kennedy. 2011. Estimating 1970–99 average annual recharge in Wisconsin using streamflow data: Reston, Virginia., U.S. Geological Survey Open-File Report 2009–1210, 14 p. plus appendixes.
Gebert, W.A., H. S. Garn, and W. J. Rose. 2016. Changes in streamflow characteristics in Wisconsin as related to precipitation and land use (ver. 1.1, January 26, 2016): U.S. Geological Survey Scientific Investigations Report 2015–5140, 23 p., and 1 appendix.
Gergely, K.J., and McKerrow, A., 2016. PAD-US—National inventory of protected areas (ver. 1.1, August 2016): U.S. Geological Survey Fact Sheet 2013–3086, 2 pp. Accessed 6.15.2022. https://pubs.usgs.gov/fs/2013/3086/.
Goebel, J.E., Mickelson, D.M., Farrand, W.R., Clayton, L., Knox, J.C., Cahow, A., Hobbs, H.C., and Walton, M.S., Jr., 1983. Quaternary geologic map of the Minneapolis 4 × 6 quadrangle, United States: U.S. Geological Survey Miscellaneous Investigations Series, Map 1-1420(NL-15), scale 1:1,000,000.
Golding, D., Swanson, R., 1986. Snow distribution patterns in clearings and adjacent forest. Water Resources Research 22. 1931–1940.
Giudice, G.D., G. Rasulo, D. Siciliano and R. Padulano. 2014. Combined effects of parallel and series detention basins for flood peak reduction. Water Resources Management 28. 3193–3205.
Gupta, S. C., A. C. Kessler, M. K. Brown, and F. Zvomuya. 2015. Climate and agricultural land use change impacts on streamflow in the upper midwestern United States. Water Resources Research 51. 5301–5317.
Gyawali, R., S. Greb, and P. Block. 2015. Temporal Changes in Streamflow and Attribution of Changes to Climate and Landuse in Wisconsin Watersheds. Journal of the American Water Resources Association. 51. 1138–1152.
Hamza, M. A., and W.K. Anderson. 2005. Soil Compaction in Cropping Systems. A Review of the Nature, Causes and Possible Solutions. Soil & Tillage Research, 82, 121–145. 10.1016/j.still.2004.08.009
Hansen, A.T., Campbell, T., Cho, S.J., Czuba, J.A., Dalzell, B.J., Dolph, C.L., Hawthorne, P.L., Rabotyagov, S., Lang, Z., Kumarasamy, K., Belmont, P., Finlay, J.C., Foufoula-Georgiou, E., Gran, K.B., Kling, C.L., and Wilcock, P. 2021. Integrated assessment modeling reveals near-channel management as cost-effective to improve water quality in agricultural watersheds. Proceedings of the National Academy of Sciences 118. p.e2024912118.
Hapner, J. A. 2006. Development of methods to assess and monitor small wetlands restored on private lands. Final report to U.S. EPA – Region V, Wetland program grant #CD96509801-0. 62 pp.
Harr, R.D., W.C. Harper, J.T. Krygier, and F.S. Hsieh. 1975. Changes in storm hydrographs after roadbuilding and clearcutting in the Oregon Coast Range. Water Resource Research 11. 436–444.
Helmers, M.J., T. Isenhart, M. Dosskey, S. Dabney, and F. Strock. 2006. Buffers and vegetative filter strips. Mississippi River Basin Symposium, Session 4-2.
Hibbert, A. R. 1969. Water yield changes after converting a forested catchment to grass. Water Resources Research 5. 634–640.
Hodgkins, G.A., R. W. Dudley, and S. S. Aichele. 2007. Historical changes in precipitation and streamflow in the U.S. Great Lakes Basin, 1915–2004: U.S. Geological Survey Scientific Investigations Report 2007–5118, 31 p.
Inamdar, S.P., S. Mostaghimi, P.W. McClellan, K.M Brannan. 2001. BMP impacts on sediment and nutrient yields from an agricultural watershed in the coastal plain region. Transactions of the American Society of Agricultural and Biological Engineers 44. 1191–1200.
Interfluve, Inc. 2003. Bayfield Peninsula stream assessment. Final Report: Fluvial geomorphology, hydrology and management recommendations. Prepared for Trout Unlimited. 93 pp.
Iron County Land Conservation Committee and Land and Water Conservation Committee. 2010. Land and water resource management plan 2010 – 2020. 102 pp. http://ironcountylcd.org/education/publications/
Jacques, J.E., and D. L. Lorenz. 1988. Techniques for estimating the magnitude and frequency of floods of ungauged streams in Minnesota. 87-4170, Water Resources Investigations Report. US Geological Survey, Washington, DC.
Janowiak, Maria K.; Iverson, Louis R.; Mladenoff, David J.; Peters, Emily; Wythers, Kirk R.; Xi, Weimin; Brandt, Leslie A.; Butler, Patricia R.; Handler, Stephen D.; Shannon, P. Danielle; Swanston, Chris; Parker, Linda R.; Amman, Amy J.; Bogaczyk, Brian; Handler, Christine; Lesch, Ellen; Reich, Peter B.; Matthews, Stephen; Peters, Matthew; Prasad, Anantha; Khanal, Sami; Liu, Feng; Bal, Tara; Bronson, Dustin; Burton, Andrew; Ferris, Jim; Fosgitt, Jon; Hagan, Shawn; Johnston, Erin; Kane, Evan; Matula, Colleen; O’Connor, Ryan; Higgins, Dale; St. Pierre, Matt; Daley, Jad; Davenport, Mae; Emery, Marla R.; Fehringer, David; Hoving, Christopher L.; Johnson, Gary; Neitzel, David; Notaro, Michael; Rissman, Adena; Rittenhouse, Chadwick; Ziel, Robert. 2014. Forest ecosystem vulnerability assessment and synthesis for northern Wisconsin and western Upper Michigan: a report from the Northwoods Climate Change Response Framework project. Gen. Tech. Rep. NRS-136. Newtown Square, PA: U.S. Department of Agriculture, Forest Service, Northern Research Station. 247 p.
Johnson, C. A., N. E. Detenbeck, and G. Niemi. 1990. The cumulative effect of wetlands on stream water quality and quantity. A landscape approach. Biogeochemistry 10. 105–141.
Jones, J. A., and G. E. Grant. 1996. Peak flow responses to clear-cutting and roads in small and large basins, western Cascades, Oregon. Water Resources Research 32. 959–974.
Kalantari, Z., S. W. Lyon, L. Folkeson, H. K. French, J. Stolte, P. Jansson and M. Sassner. 2014. Quantifying the hydrological impact of simulated changes in land use on peak discharge in a small catchment. Science of the Total Environment 466–467. 741–754.
Krog, C. 1996. The Retreat of Farming and the Return of Forests in Wisconsin’s Cutover; Continuity and Change in Marinette County. Voyageur Winter/Spring. 2–12.
Krug, W.R., D. H. Conger, and W. A. Gebert. 1992. Flood-frequency characteristics of Wisconsin streams. US Geological Survey Water Resources Investigation Report 91-4128. US Geological Survey, Madison, WI.
Langdale, G.W., R.L. Wilson, and R.R. Bruce. 1990. Cropping frequencies to sustain long-term conservation tillage systems. Soil Science Society of America Journal 54. 193–198.
Larson, C., 2020. Diverse Allochthonous Resource Quality Effects on Headwater Stream Communities through Insect-Microbe Interactions. Doctoral dissertation, Michigan State University.
Lenters, J.D., 2004. Trends in the Lake Superior water budget since 1948—A weakening seasonal cycle: Journal of Great Lakes Research. 30, 20–40.
Lenz, B. N., D. A. Saad and F. A. Fitzpatrick. 2003. Simulation of ground-water flow and rainfall runoff with emphasis on the effects of land cover, Whittlesey Creek, Bayfield County, Wisconsin, 1999–2001. Water-Resources Investigations Report 03–4130. 47 pp.
Lewandowski, A., L. Everett, C. Lenhart, K. Terry, M. O Ringer, and R. Moore. 2015. Fields to streams. Managing water in rural landscapes. Part Two, Managing Sediment and Water. A publication of the University of Minnesota Water Resources Center. University of Minnesota Extension. 39 pp.
Loarie, S.R., P.B. Duffy, H. Hamilton, G.P. Asner, C.B. Field, and D.D. Ackerly. 2009: The velocity of climate change. Nature 462. 1052–1055.20033047
Lytle, D.H. and Poff, N.L. 2004. Adaptation to Natural Flow Regimes. Trends in Ecology and Evolution. 19. 94–100. 10.1016/j.tree.2003.10.002 16701235
MPCA. 2016. Minnesota Stormwater Manual. Minnesota Pollution Control Agency. Accessed 6.15.2022. https://stormwater.pca.state.mn.us/index.php?title=Main_Page
Mahl, U.H., Tank, J.L., Roley, S.S. and Davis, R.T. 2015. Two-stage ditch floodplains enhance N-removal capacity and reduce turbidity and dissolved P in agricultural streams. Journal of the American Water Resources Association 51. 923–940.
Martin, L.D. 2019. A Tree-ring fire history of the Upper Bois Brule River, Northwest Wisconsin. University of Minnesota. Doctoral Dissertation, University of Minnesota.
Miller, R. and Bender, B. 2008. Growth and Yield of Poplar and Willow Hybrids in the Central Upper Peninsula of Michigan. Presented at the “Woody Biomass from Forest and Fields: Opportunities for Northern WI Conference” April 2008.
Miller, J. and Nicholson, S. W. 2013. Geology and mineral deposits of the 1.1 Ga Midcontinent Rift in the Lake Superior region–an overview. Field guide to the copper-nickel-platinum group element deposits of the Lake Superior Region. Edited by Miller, J. Precambrian Research Center Guidebook: 13–01.
Mitchell, N., 2015. Achieving peak flow and sediment loading reductions through increased water storage in the Le Sueur watershed, Minnesota: A modeling approach. M.S. Thesis: University of Minnesota Duluth, 117 p.
Mitchell, N., Kumarasamy, K., Cho, S.J., Belmont, P., Dalzell, B. and Gran, K., 2018. Reducing high flows and sediment loading through increased water storage in an agricultural watershed of the upper Midwest, USA. Water 10. 1053.
Murray, C.D. and J.M. Buttle. 2003. Impacts of clear-cut harvesting on snow accumulation and melt in a northern hardwood forest. Journal of Hydrology 271. 197–212.
Muss, J. 2011. Forested watershed hydrology: How forest pattern and canopy structure control snow accumulation and melt processes in northwestern Wisconsin. Doctoral Dissertation, University of Wisconsin, Madison. 206 pp.
NASS (National Agricultural Statistics Service). 2012. USDA Census of Agriculture. National Agricultural Statistics Service. Accessed 6.15.2022. https://www.nass.usda.gov/index.php
NRCS (Natural Resources Conservation Service). 2014. Planning, design, management and maintenance of vegetative filter strips (VFS). Companion document for Wisconsin Practice Standard 393 Filter Strip. WI Agronomy Technical Note 10. Accessed 6.15.2022. https://socwisconsin.org/wp-content/uploads/2015/01/WIAgronomyTechNote10_BroadReview.pdf
Naderman, G.C., B.G. Brock, G.B. Reddy, and C.W. Raczkowski. 2006. Long-term no-tillage: effects on soil carbon and soil density within the prime crop root zone. Project Report to the Corn Growers Association of North Carolina, Cotton Incorporated, and the North Carolina Soybean Producers Association.
Naiman R. J., C. A. Johnston, and J. C. Kelley. 1988. Alteration of North American Streams by Beaver: The structure and dynamics of streams are changing as beaver recolonize their historic habitat. BioScience 38. 753–762.
National Weather Service, 2021. Major June Flooding in the Northland. National Oceanic and Atmospheric Administration. Accessed 6.15.2022. https://www.weather.gov/dlh/June15-17_2018flooding.
Nejadhashemi, A., B. Wardynski, J. Munoz, and A. Nejadhashemi. 2012. Large-scale Hydrologic Modeling of the Michigan and Wisconsin agricultural regions to study impacts of land use changes. Transactions of the American Society of Agricultural and Biological Engineers 55. 821–838.
Need, E. A., and M. D. Johnson. 1984. Stratigraphy and history of glacial deposits along Wisconsin’s Lake Superior shoreline—Wisconsin Point to Bark Point: Geoscience Wisconsin 9. 21–51.
Neff, Brian P., and Nicholas, J.R. 2005. Uncertainty in the Great Lakes Water Balance: U.S. Geological Survey Scientific Investigations Report 2004-5100, 42 p.
Nicholson, S.W. 2006. Bedrock geologic map of the Port Wing, Solon Springs, and parts of the Duluth and Sandstone 30’× 60’quadrangles, Wisconsin. No. 2869. U.S. Geological Survey.
NOAA (National Oceanic and Atmospheric Administration). 2019. Flood-Control Investments Bring Big Returns. NOAA Office for Coastal Management. Accessed 6.15.2022. https://coast.noaa.gov/states/stories/flood-control-investments-bring-big-returns.html
NOAA and NWS (National Oceanographic and Atmosphere Administration and National Weather Service) 2021. Average Snowfall Totals for Northeastern Wisconsin. Accessed 6.15.2022. https://www.weather.gov/grb/avgsnow#:~:text=Average%20seasonal%20snowfall%20totals%20range,snowbelt%20region%20of%20Vilas%20County.
Olcott, P. G., D. W. Ericson, P. E. Felsheim, and W. L. Broussard. 1978. Water resources of the Lake Superior Watershed, northeastern Minnesota. Hydrologic Investigations Atlas, US Geological Survey, Deptartment of the Interior with the Minnesota Department of Natural Resources, Division of Water, Soil, and Minerals, HA-582.
Pankau, R.C., J.E. Schoonover, K.W.J. Williard, and P.J. Edwards. 2012. Concentrated flow paths in riparian buffer zones of southern Illinois. Agroforestry Systems 84. 191–205.
Peppler, M. C. 2006. Effects of magnitude and duration of large floods on channel morphology: A case study of North Fish Creek, Bayfield County, Wisconsin, 2000-2005. Master’s degree thesis, University of Wisconsin Madison, 109 pp.
Perica, S., D. Martin, S. Pavlovic, I. Roy, M. St. Laurent, C. Trypaluk, D. Unruh, M. Yekta, and G. Bonnin. 2014. NOAA Atlas 14 precipitation-frequency atlas of the United States. Volume 8 Version 2.0: Midwestern states (Colorado, Iowa, Kansas, Michigan, Minnesota, Missouri, Nebraska, North Dakota, Oklahoma, South Dakota, Wisconsin). U.S. Department of Commerce, National Oceanic and Atmospheric Administration, National Weather Service, Silver Spring, Maryland.
Perry, C. H., R. C. Miller, and K. N. Brooks. 2001. Impacts of short rotation hybrid poplar plantations on regional water yield. Forest Ecology and management 143. 143 – 151.
Poff, N. L. and J. V. Ward. 1989. Implications of streamflow variability and predictability for lotic community structure: A regional analysis of streamflow patterns. Canadian Journal of Fisheries and Aquatic Sciences 46. 1805–1818.
Pomeroy, J.W., R. J. Granger, A. Pietroniro, J. E. Elliott, B. Toth, N. Hedstrom. 1997. Hydrological pathways in the Prince Albert Model Forest. Final report submitted to the Prince Albert Model Forest Association. National Hydrological Research Institute, Environment Canada, Saskatoon, 154 pp.
Potter, K. W. 1991. Hydrological impacts of changing land management practices in a moderate sized agricultural catchment. Water Resources Research 27. 845–855.
Powell, G.E., Ward, A.D., Mecklenburg, D.E. and Jayakaran, A.D., 2007. Two-stage channel systems: Part 1, a practical approach for sizing agricultural ditches. Journal of Soil and Water Conservation 62. 277–286.
Pratt, D. and B. Blust. 2005. Little streams feed a big fishery. Wisconsin Natural Resources Magazine December 2005.
Price, A.G. and D. E. Carlyle-Moses. 2003. Measurement and modelling of growing-season canopy water fluxes in a mature mixed deciduous forest stand, southern Ontario, Canada. Agricultural and Forest Meteorology 119. 69–85.
RCIC (Red Clay Interagency Committee). 1964. Second progress report: Madison, Wis., Soil Conservation Board, 40 p.
RCIC (Red Clay Interagency Committee). 1977. 1976 Evaluation of RCIC works project: Madison, Wis., Soil Conservation Board, 56 pp.
Raper, R.L., D.W. Reeves, J.N. Shaw, E. van Santen, and P.L. Mask. 2005. Using site-specific subsoiling to minimize draft and optimize corn yields. Transactions of the American Society of Agricultural Engineers 48. 2047–2052.
Raper, R.L., D.W. Reeves, J.N. Shaw, E. van Santen, and P.L. Mask. 2007. Site-specific subsoiling benefits for cotton production in Coastal Plains soils. Soil and Tillage Research 96. 174–181.
Rhemtulla, J. M., D. J. Mladenoff, and M.K. Clayton. 2009. Legacies of historical land use on regional forest composition and structure in Wisconsin, USA (mid 1800s – 1930s – 2000s). Ecological Applications 19. 1061–1078.19544743
Riedel, M.S., E. S. Verry, and K.N. Brooks. 2001. Land use impacts on fluvial processes in the Nemadji River Watershed. Hydrological Science and Technology 18. 197–206.
Riedel, M.S., E. S. Verry, and K.N. Brooks. 2005. Impacts of land use conversion on bankfull discharge and mass wasting. Journal of Environmental Management 76. 326–337.15932785
Saunders, S., D. Findlay, T. Easley, and T. Spencer. 2012. Doubled trouble: more Midwestern extreme storms. Louisville, CO: Rocky Mountain Climate Organization; New York, NY: Natural Resources Defense Council. 42 p.
Schaetzl, R. J., and M.L. Thompson. 2015. Soils: genesis and geomorphology. Cambridge University Press.
Schottler, S., J. Ulrich, and D. Engstrom. 2016. Comment on “Climate and agricultural land use change impacts on streamflow in the Upper Midwestern United States” by Satish C. Cupta et al. Water Resources Research 52. 6691–6698.
Shultz, S.D. 2003. Best management practice guidelines for the Wisconsin portion of the Lake Superior Basin. Prepared for the Wisconsin Department of Natural Resources and ABDI. Stable Solutions.
Schaake, J. C., and L. Chunzhen. 1989. Development and application of simple water balance models to understand the relationship between climate and water resources. New Directions for Surface Water Modeling, Proceedings of the Baltimore Symposium, May 1989. 10 pp.
Sheridan, J. M., Lowrance R., and Bosch, D. D. 1999. Management effects on runoff and sediment transport in riparian forest buffers. Transactions of the American Society of Agricultural Engineers 42. 55–64
Schilling, K. E. 2016. Comment on “Climate and agricultural land use change impacts on streamflow in the upper midwestern United States” by Satish C. Gupta et al. Water Resources Research 52. 5694–5696.
Sisk, T.D., editor. 1998. Perspectives on the land-use history of North America: a context for understanding our changing environment. U.S. Geological Survey, Biological Resources Division, Biological Science Report USGS/ BRD/BSR-1998-0003. 104 pp. Accessed 6.15.2022. https://conservancy.umn.edu/bitstream/handle/11299/165997/USGS%201998.pdf?sequence=1&isAllowed=y
Slesak, Robert A., Lenhart, Christian F., Brooks, Kenneth N., D’Amato, Anthony W., and Palik, Brian J. 2014. Water table response to harvesting and simulated emerald ash borer mortality in black ash wetlands in Minnesota, USA. Canadian Journal of Forest Research 44. 961–968.
Smakhtin, V. U. 2000. Low flow hydrology: a review. Journal of Hydrology 240. 147–186.
Steen-Adams, M.M., D. Mladenoff, N. Langston, F. Liu, and J. Zhu. 2011. Influence of biophysical factors and differences in Ojibwe reservation versus Euro-American social histories on forest landscape change in northern Wisconsin, USA. Landscape Ecology 26. 1165–1178.
Stuntebeck, T.D., M. J. Komiskey, M. C. Peppler, D. W. Owens and D. R. Frame. 2011. Precipitation-runoff relations and water-quality characteristics at edge-of-field stations, Discovery Farms and Pioneer Farm, Wisconsin, 2003–8: U.S. Geological Survey Scientific Investigations Report 2011–5008, 46 pp.
Swanston, C., M. Janowiak, L. Iverson, L. Parker, D. Mladenoff, L. Brandt, P. Butler, M. St. Pierre, A. Prasad, S. Matthews, M. Peters, and D. Higgins. 2010. Ecosystem vulnerability assessment and synthesis: a report for the climate change response framework project at Chequamegon-Nicolet National Forest, version 1. Accessed 6.15.2022. https://www.fs.fed.us/nrs/pubs/gtr/gtr_nrs82.pdf
Syverson, K. M., and P. M. Colgan. 2004. The quaternary of Wisconsin: a review of stratigraphy and glaciation history. Quaternary glaciations extent and chronology part II: North America. Edited by J. Ehlers and PL Gibbard. Elsevier BV, Amsterdam, The Netherlands. pp 295–311.
Troendle, C.A. and Leaf, C. F. 1980. Hydrology. An approach to water resources evaluation of non-point silviculture sources. EPA-600/8-80-012. US Environmental Protection Agency, Athens, GA. 173 p.
Turville-Heitz, M. 1999. Lake Superior Basin water quality management plan: A five year plan to protect and enhance our water resources. Wisconsin Department of Natural Resources. March. PUBL-WT-278-99-REV.
Tushingham, A M., and W. R. Peltier. 1992. Validation of the ICE-3G Model of Würm-Wisconsin Deglaciation using a global data base of relative sea level histories. Journal of Geophysical Research: Solid Earth. 97. 3285–3304 doi:10.1029/91jb02176
USDA, 2015. CropScape – Cropland Data Layer. U.S. Department of Agriculture. Accessed 6.15.2022. http://nassgeodata.gmu.edu/CropScape/
Varhola, A., N. Coops, M. Weiler, and R. Dan Moore. 2010. Forest canopy effects on snow accumulation and ablation: An integrative review of empirical results. Journal of Hydrology 392. 219–233.
Vermont DEC (Department of Environmental Conservation). 2022. Wetland functions and values: Water storage for flood water and storm runoff. Accessed 6.15.2022. https://dec.vermont.gov/watershed/wetlands/functions/storage
Verry, E.S. 1983. Aspen clearcutting increases snowmelt and storm flow peaks in North Central Minnesota. Journal of the American Water Resources Association 19. 59–67.
Verry, E.S., 1986. Forest Harvesting and Water: The Lake States Experience Journal of the American Water Resources Association 22. 1039–1047.
Verry, E. S., K. N. Brooks, and P. K. Barten. 1988. Streamflow response from an ombrotrophic mire. In: Proceedings of the international symposium on the hydrology of wetlands in temperate and cold regions, Joensuu, Finland June 6 – 6, 1988, pp 52–59.
Verry, E.S. 2001. Land fragmentation and impacts to streams and fish in the central and upper Midwest. In: Proceedings, Society of American Foresters 2000 National Convention. SAF Publ. 01-02. Bethesda, MD. Society of American Foresters, p. 38–44.
Verry, E. S. 2005. Understanding watershed level impacts to streams and stream geomorphology. Presentation at Forest Roads: Wetland and stream crossings. Lake Nebagamon, WI, June 16-17.
Veum, K. S., K. W. Goyne, P. P. Motavalli and R. P. Udawatta. 2009. Runoff and dissolved organic carbon loss from a paired-watershed study of three adjacent agricultural watersheds. Agriculture, Ecosystems and Environment 130. 115–122.
WDNR (Wisconsin Department of Natural Resources). 1994. The Wisconsin Stormwater Manual. Part One: Overview. Wisconsin Department of Natural Resources PUB-WR=349-94.
WDNR (Wisconsin Department of Natural Resources). 2010. Lake Superior Basin regional assessment & report compendium. Wisconsin Department of Natural Resources PUB-FR-468-2010. 85 pp.
WDNR (Wisconsin Department of Natural Resources). 2011. Wisconsin Forest management Guidelines. Wisconsin Department of Natural Resources PUB-FR-226.
Wisconsin Department of Natural Resources. 2015. The ecological landscapes of Wisconsin: An assessment of ecological resources and a guide to planning sustainable management. Wisconsin Department of Natural Resources, PUB-SS-1131 2015, Madison
WDNR (Wisconsin Department of Natural Resources). 2015b. Ecological landscapes of Wisconsin: an assessment of ecological resources and a guide to planning sustainable management. PUB-SS-1131 2015, Madison.
WDNR (Wisconsin Department of Natural Resources). 2019. Land Cover Data: WISCLAND 2.0. Accessed 6.15.2022. https://dnr.wisconsin.gov/maps/WISCLAND.
Wisconsin Initiative on Climate Change Impacts (WICCI). 2022. Wisconsin’s Changing Climate: Trends and Projections. Nelson Institute for Environmental Studies, University of Wisconsin-Madison and the Wisconsin Department of Natural Resources, Madison Wisconsin. Accessed 6.15.2022. https://wicci.wisc.edu/wisconsin-climate-trends-and-projections/
Wisconsin’s Changing Climate: Impacts and Adaptation. 2011. Wisconsin Initiative on Climate Change Impacts. Nelson Institute for Environmental Studies, University of Wisconsin-Madison and the Wisconsin Department of Natural Resources, Madison, Wisconsin.
Walker, J. F. and W. R. Krug. 2003. Flood frequency characteristics of Wisconsin streams. US Geological Survey. Water-Resources Investigations Report 03–4250. 37 pp.
Walker, J.F., Peppler, M.C., Danz, M.E., and Hubbard, L.E. 2017. Flood-frequency characteristics of Wisconsin streams (ver. 2.2, April 2020): Reston, Virginia, U.S. Geological Survey Scientific Investigations Report 2016–5140, 33 p., 1 plate, 2 appendixes, 10.3133/sir20165140.
Wang, l., J. Lyons, and P. Kanehl. 2002. Effects of watershed best management practices on habitat and fish in Wisconsin Streams. Journal of the American Water Resources Association 38. 663–680.
Wemple, B.C, J.A Jones, and G.E. Grant. 1996. Channel network extension by logging roads in two basins, western Cascades, Oregon. Water Resources Bulletin 32. 1195–1207.
Westbrook, C., C. David and B. Bruce. 2006. Beaver dam and overbank floods influence groundwater-surface water interactions of a Rocky Mountain riparian area. Water Resources Research - WATER RESOUR RES. 42. 10.1029/2005WR004560.
Cooperative Extension Service. 1994. “What Is Conservation Tillage?” Conservation Tillage Series, Purdue University. Accessed 6.15.2022. https://www.extension.purdue.edu/extmedia/ct/ct-1.html.
Wheaton J.M., Bennett S.N., Bouwes, N., Maestas J.D. and Shahverdian S.M. (Editors). 2019. Low-Tech Process- Based Restoration of Riverscapes: Design Manual. Version 1.0. Utah State University Restoration Consortium. Logan, UT. Available at: http://lowtechpbr.restoration.usu.edu/manual.
Wisconsin Forestry BMPs for Water Quality. 2010. https://erc.cals.wisc.edu/woodlandinfo/files/2017/09/FR-093.pdf
Wisconsin Wetland Association. 2018. Exploring the Relationship between Wetlands and Flood Hazards in the Lake Superior Basin.
Wright, H. E. 1971. Retreat of the Laurentide ice sheet from 14,000 to 9000 years ago. Quaternary Research 1. 316–330.
Wright, H.E. Jr.; Watts, William A.; Jelgersma, Saskia; Waddington, Jean C.B.; Ogawa, Junko; Winter, T.C. 1969. SP-11 Glacial and Vegetational History of Northeastern Minnesota. Minnesota Geological Survey. Retrieved from the University of Minnesota Digital Conservancy, https://hdl.handle.net/11299/59962.
Zalesny Jr, R.S., Berndes, G., Dimitriou, I., Fritsche, U., Miller, C., Eisenbies, M., Ghezehei, S., Hazel, D., Headlee, W.L., Mola-Yudego, B. and Negri, M.C., 2019. Positive water linkages of producing short rotation poplars and willows for bioenergy and phytotechnologies. Wiley Interdisciplinary Reviews: Energy and Environment 8. p.e345.
Zheng, X., Tarboton, D.G., Maidment, D.R., Liu, Y.Y., and Passalacqua, P. 2018. River Channel Geometry and Rating Curve Estimation Using Height above the Nearest Drainage. Journal of the American Water Resources Association 54. 785–806.