# Appendix 1 Summary of Input

This paper has undergone the official DNR internal review required for publication. Along the way, we have also reached out to resource managers in the basin for feedback and review. This effort started in 2015 as a task of a work group that included managers who were interested in the creation of this document to summarize past work and provide information on how to prioritize work areas. This group of people has been included throughout the writing process. In 2020 as the draft became more final an opportunity for feedback was provided by WDNR and WWA. In 2022 the Slow the flow team was re-invigorated as a working group of the Lake Superior Collaborative. At the 2022 Lake Superior Collaborative Symposium, we shared a draft of the executive summary and recommendations with participants. Below is the feedback we received throughout the writing process. We include documentation of this feedback to help inform future work. We thank everyone who has provided feedback and support for this report.

[underlined: Lake Superior Collaborative Symposium feedback]

- Need to consider incorporating preventing the movement of seed banks from place to place when hauling fill, moving equipment, etc. for Slow the Flow projects, and properly cleaning equipment before moving into contracts.
- There is a lack of Traditional Ecological knowledge within this document. For future work, we would like to gain a better understanding of how these practices may integrate into STF efforts in the basin. More needs to be done to incorporate TEK in Decision making.
- There is a need to institute bankfull width as a standard for all stream crossing replacements.
- In the future, it would be interesting to connect slow the flow efforts with FEH to the susceptibility of flood energy overcoming the resistance potential of channels upstream of road crossings.
- It would be useful to connect the hydrologic hot spots found in slow the flow with erosion potential and then link to headwater wetlands, ditching, and mass-wasting potential.
- Moving forward it might be useful to work with UW extension, and others to distill Slow the Flow information for different sectors (Forest, Ag, Urban, etc.) and landowners, and managers.
  ○ This will aid in the implementation of recommendations. It is suggested that work groups are created for each sector under the L.S. Collaborative slow the flow work group.
  ○ Workshops to share information by sector may be helpful to share recommendations
  ○ Suggest the creation of topic-specific info pages to spark interest and make the larger doc more absorbable, such as factsheets targeted towards user groups.

Reviewers Comments:

It is known that soil health is connected to slow the flow and water quality. NPS recommendations focus on soil health, particularly increasing the % of organic matter in the soils. In other clay soils, more current WI NPS strategies include increasing the organic carbon content of the soils to increase infiltration, even in clay soils. This involves a suite of BMPs (mostly in row crop settings) that include continuous cover, no-till or low till, and low disturbance manure application. These relationships should be explored more in the future and how they apply in the Lake Superior Basin.

There are additional policy options that could be explored such as runoff trading. Wisconsin has an established P trading framework and an adaptive management strategy associated with WPDES permits. Streambank stabilization is included in the trading program framework and there are existing trades that include this practice. How this applies to slow the flow work in the Lake Superior basin should be investigated further.