# CONTRIBUTORS | REVIEWERS

## EPA Office of Research and Development (ORD) Authors

Mike DeVito | U.S. EPA/ORD/CCTE
Alison Harrill | U.S. EPA/ORD/CCTE
Russell Thomas | U.S. EPA/ORD/CCTE

## Risk Sciences International

EPA Contract 68HE0B22P0318

Shintaro Hagiwara | RSI
Daniel Krewski | RSI
Greg Paoli | RSI
Patrick J. Farrell | RSI

## EPA ORD Executive Direction

Russell Thomas | CCTE Center Director
Reeder Sams | CCTE Deputy Center Director
Alison Harrill | CCTE Associate Director
Mike DeVito | CCTE/CCED Division Director

## EPA Contributors and Reviewers

Timothy Buckley | U.S. EPA/ORD/CCTE
Chris Dockins | U.S. EPA/NCEE
Peter Egeghy | U.S. EPA/ORD/CCTE
Katie Paul-Friedman | U.S. EPA/ORD/CCTE
Joshua Harrill | U.S. EPA/ORD/CCTE
Bryan Hubbell | U.S. EPA/ORD/NPD for Air, Climate, and Energy
Kristin Isaacs | U.S. EPA/ORD/CCTE
Richard Judson | U.S. EPA/ORD/CCTE
Jason Lambert | U.S. EPA/ORD/CCTE
Esra Mutlu | U.S. EPA/ORD/CCTE
Jon Sobus | U.S. EPA/ORD/CCTE
Ravi Subramaniam | U.S. EPA/ORD/CPHEA
Kristina Thayer | U.S. EPA/ORD/CPHEA
Daniel Villeneuve | U.S. EPA/ORD/CCTE