# 6 VOI CASE STUDY RESULTS

## 6.1 VOI ANALYSIS OF ETAP VERSUS THHA

### 6.1.1 BENEFIT-RISK DECISION MAKING

The BRDM seeks an optimal reduction in exposure to balance the costs associated with exposure mitigation against the corresponding public health benefit. The results of the VOI analysis for the BRDM and the nine baseline scenarios corresponding to each of the nine categories in the 3×3 grid of SHEDS-HT exposures (Figure 5-2) are summarized in Figure 6-1 and Table 6-1. The results for Baseline Scenario 5, in which both μ_exp_ and σ_exp_ are assigned to the middle categories in this grid, are used as the starting point for the discussion of the results, followed by evaluation of the results for lower and higher values of μ_exp_ and σ_exp_.

In Baseline Scenario 5, EV|CI is $293B. This value represents the ETSC minimized over the 20-year time horizon, without collecting any additional information, obtained by proportionately reducing exposure by the optimal value of 78% (i.e., the ORE is 78%). The EVIPPI, which represents the reduction in the ETSC obtained with immediate perfect information about μ_tox_ for the chemical of interest, is $154B. This implies that the ETSC may be reduced by up to 52% by eliminating uncertainty in μ_tox_.

In the presence of experimental error (neither test can completely eliminate uncertainty), ETAP and THHA can reduce the ETSC by as much as $133B and $143B, respectively, as indicated by their EVISI values. These EVISIs account for 87% and 93% of EVIPPI value, respectively, indicating that the value of information for both ETAP and THHA is high. What distinguishes these two approaches is the time required to obtain the results of the toxicity testing and human health assessment. As the delay associated with ETAP is only 6 months, with the THHA taking 8 years to complete, their CODs - $12B for ETAP and $169B for THHA - are notably different. In fact, the COD for THHA is greater than its EVISI, resulting in a negative value for EVDSI_THHA_ of -$26B, while EVDSI_ETAP_ remains positive at $121B. The comparison of EVDSI values for these two toxicity testing strategies indicates that the greater timeliness of ETAP provides a distinct advantage over THHA, despite the smaller uncertainty reduction associated with ETAP. As the direct COT for ETAP is only $200K per test, the value of ENBS_ETAP_=$121B indicates that ETAP is preferable when the delay and costs of testing are considered. When the VOI is assessed in terms of ROI, the ETSC is reduced by $603,877 for every $1 spent on ETAP. For THHA, since the EVDSI is negative, so are the ENBS and ROI.

In considering scenarios for which μ_exp_ and σ_exp_ are higher or lower than their central values (Figure 6-1), Baseline Scenario 8 - where μ_exp_ is taken from the highest SHEDS-HT exposure category while σ_exp_ remains in the medium category - shows an increase in both ORE and EV|CI due to the shift to the right in the prior uncertainty distribution for the population average risk R compared to Baseline Scenario 5. Since the BRDM cannot take regulatory action while waiting for the results of ETAP or THHA, the CODs for both assays are increased by more than 5-fold compared to Baseline Scenario 5, whereas the EVIPPI and EVISI values are reduced in Baseline Scenario 8. Therefore, EVDSI, ENBS, and ROI are all reduced in Baseline Scenario 8.

In Baseline Scenario 2, on the other hand, where μ_exp_ is in the lowest SHEDS-HT exposure category, the ORE and EV|CI are reduced compared to Baseline Scenario 5, leading to much smaller CODs for both ETAP and THHA. In this case, the reduced COD for THHA translates to positive EVDSI, ENBS, and ROI values; however, ETAP remains the preferred testing and assessment strategy in this scenario.

As shown in Figure 6-1, the relative performance of the two toxicity testing and assessment approaches for increased or decreased values of σ_exp_ is less impactful than the increase/decrease in μ_exp_ (Baseline Scenarios 7, 8, and 9 show similar VOI metrics). However, both ETAP and THHA produced negative EVDSI values (along with ENBS and ROI values) in Baseline Scenario 9. This indicates that there are situations where immediate exposure mitigation action based on current information may be preferable to collecting additional toxicity information.

The timeliness of toxicity testing appears to be the dominant factor in determining the VOI of ETAP and THHA, despite EVISI_THHA_ accounting for at least 79% of EVIPPI in all nine scenarios. Timeliness is especially critical when the potential risk is high, as earlier intervention can provide a substantial reduction in health cost. This is consistent with negative EVDSI, ENBS, and ROI values for THHA in more than half of the scenarios considered (Baseline Scenarios 5 to 9), where exposure is higher. In contrast, ETAP, which provides toxicity testing data within 6 months, produced positive EVDSI, ENBS, and ROI values in Baseline Scenarios 1 to 8.

By considering the posterior uncertainty distribution for risk, the probability of making a decision to implement exposure mitigation action can be estimated for any combination of decision-making principle and toxicity test. Table 6-2 summarizes the probability of making decisions under benefit-risk decision making for the ETAP and THHA; decision-making probabilities in the hypothetical case of partial perfect information (PPI) in which the value of μ_tox_ is assumed to be known are also given for purposes of comparison. Since the ETAP is subject to larger posterior uncertainty about μ_tox_ than THHA, ETAP results in more decisions to regulate in cases where perfect knowledge of μ_tox_ would not lead to regulatory action as compared to THHA.

As discussed in Section 4.3, uncertainty reduction informed by additional toxicity testing data is of value when the prior and posterior decisions differ. This is most likely to be the case in scenarios in which the ORE is neither 0% nor 100% (Baseline Scenarios 4-6), which demonstrate greater EVIPPI, EVISI_ETAP_, and EVISI_THHA_ values. The COD increases with increasing delay, due to the greater opportunity loss in earlier exposure mitigation; increasing ORE can enhance the increase in the COD.

Figure 6-1 Selected VOI metrics for baseline VOI analysis for BRDM.

Figure 6 1. Selected VOI metrics for baseline VOI analysis for BRDM.

Table 6-1 Baseline VOI analysis for BRDM^a^

μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
ORE | 0 | | 0 | | 0 | | 52 | | 78 | | 88 | | 100 | | 100 | | 100
EV\|CI ($B) | 35 | | 71 | | 53 | | 187 | | 293 | | 326 | | 683 | | 718 | | 915
EVIPPI ($B) | 10 | | 24 | | 15 | | 113 | | 154 | | 146 | | 119 | | 122 | | 74
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 7 | 8 | 18 | 21 | 11 | 12 | 98 | 105 | 133 | 143 | 126 | 135 | 86 | 101 | 88 | 103 | 47 | 59
CoD ($B) | 0.3 | 5 | 1 | 12 | 0.5 | 7 | 6 | 85 | 12 | 169 | 12 | 172 | 65 | 876 | 70 | 952 | 100 | 1,342
EVDSI ($B) | 6 | 3 | 18 | 9 | 10 | 5 | 92 | 20 | 121 | −26 | 113 | −36 | 22 | −775 | 17 | −849 | −53 | −1,283
ENBS($B) | 6 | 3 | 18 | 9 | 10 | 5 | 92 | 20 | 121 | −26 | 113 | −36 | 22 | −775 | 17 | −849 | −53 | −1,283
ROI | 32,140 | 856 | 87,618 | 2,226 | 50,901 | 1,327 | 461,668 | 5,046 | 603,877 | −6,478 | 566,612 | −9,124 | 107,737 | −193,780 | 86,693 | −212,216 | −262,718 | −320,868

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric)

Table 6-2 Probability (%) of making a decision to regulate or not regulate a chemical for BRDM^a,b^

μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
| P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0)
PPI | 10.6 | 89.4 | 17.1 | 82.9 | 14.7 | 85.3 | 19.8 | 80.2 | 32.6 | 67.4 | 48.0 | 52.0 | 67.4 | 32.6 | 67.4 | 32.6 | 82.9 | 17.1
ETAP | 9.9 | 90.1 | 20.0 | 80.0 | 15.4 | 84.6 | 31.3 | 68.7 | 44.7 | 55.3 | 58.8 | 41.2 | 82.4 | 17.6 | 82.4 | 17.6 | 91.5 | 8.5
THHA | 10.2 | 89.8 | 18.6 | 81.4 | 14.0 | 86.0 | 24.1 | 75.9 | 40.7 | 59.3 | 51.9 | 48.1 | 75.9 | 24.1 | 75.9 | 24.1 | 88.0 | 12.0

a D=1 indicates a decision to regulate, and D=0 denotes a decision not to regulate.

b Partial perfect information (PPI) assumes perfect knowledge of μ_tox_.

### 6.1.2 TARGET-RISK DECISION-MAKING

The results for the VOI analysis for the TRDM, under which decisions are made without consideration of cost, are summarized in Table 6-3. In all nine baseline scenarios, the TRL lies between the q_L_ and q_U_ of the prior uncertainty distribution for the population average risk R; consequently, the TRDM must collect additional toxicity test data in order to make a decision on whether or not to regulate. This decision-making paradigm is depicted in Figure 6-2 under the conditions of Baseline Scenario 5.

Figure 6-2 Cumulative distribution function for prior uncertainty distribution for R in log_10_ scale (Baseline Scenario 5). The black vertical line represents the median risk, while the yellow and red vertical lines denote q05 and q95, respectively. The purple dotted line represents the TRL=10^−6^.

Figure 6 2. Cumulative distribution function for prior uncertainty distribution for R in log10 scale (Baseline Scenario 5). The black vertical line represents the median risk, while the yellow and red vertical lines denote q05 and q95, respectively. The purple dotted line represents the TRL=10−6.

In Baseline Scenario 5, the EV|CI (corresponding to the ETHC without exposure mitigation action) is $446B, indicating that some of the chemicals with exposure information within this domain may pose an appreciable risk to the exposed population. As the EVIPPI is $323B, eliminating uncertainty in μ_tox_ could reduce the ETHC by as much as 72%. From Table 6-4, perfect information about μ_tox_ would allow the TRDM to decide to regulate (or not regulate) 35% (or 13%) of the chemicals within this domain. For the remaining 52% of the chemicals, even PPI is insufficient to allow the TRDM to make an unambiguous risk determination relative to TRL and thus a regulatory decision. With the ETAP and THHA, the TRDM can decide to regulate 22% and 28% of chemicals in this domain, respectively. If regulatory action is taken immediately, the ETHC is reduced by EVISI_ETAP_=$297B for the ETAP and EVISI_THHA_=$314B for the THHA. As the delay in obtaining the THHA is longer than ETAP, the CODs differ markedly, with COD_THHA_ being more than 14-fold larger than COD_ETAP_. Consequently, EVDSI_ETAP_ is over 2-fold greater than EVDSI_THHA_. The lower testing cost of the ETAP further increases the value of information when measured in terms of return on investment, with ROI_ETAP_=1,420,115 being 42-fold greater than ROI_THHA_=33,678.

Examination or other exposure scenarios reveals that all VOI metrics increase when either μ_exp_ or σ_exp_ increase. This is due to the associated uncertainty distribution for R being shifted towards higher population risk levels. With the exception of Baseline Scenario l, EVDSI, ENBS, and ROI are all greater for ETAP than for THHA, due to the shorter testing and assessment development time for ETAP. Although EVDSI and ENBS are greater for THHA in Baseline Scenario 1, ROI for ETAP remains higher (as is the case for all other scenarios).

Figure 6-3 Selected VOI metrics for baseline VOI analysis for TRDM.

Figure 6 3. Selected VOI metrics for baseline VOI analysis for TRDM.

Table 6-3 Baseline VOI analysis for TRDM^a^.

μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
EV\|CI ($B) | 35 | | 71 | | 53 | | 231 | | 446 | | 492 | | 2,115 | | 2,281 | | 3,205
EVIPPI ($B) | 0.2 | | 14 | | 17 | | 170 | | 323 | | 342 | | 1,443 | | 1,566 | | 2,086
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 0.01 | 0.04 | 4 | 7 | 8 | 12 | 143 | 162 | 297 | 314 | 332 | 339 | 1,389 | 1,425 | 1,545 | 1,561 | 2,067 | 2,078
CoD ($B) | 0.00 | 0.03 | 0.2 | 4 | 0.3 | 7 | 6 | 92 | 13 | 180 | 14 | 194 | 59 | 814 | 66 | 892 | 88 | 1,187
EVDSI ($B) | 0.01 | 0.02 | 4 | 3 | 7 | 5 | 137 | 69 | 284 | 135 | 318 | 145 | 1,330 | 611 | 1,479 | 669 | 1,979 | 890
ENBS($B) | 0.01 | 0.02 | 4 | 3 | 7 | 5 | 137 | 69 | 284 | 135 | 318 | 145 | 1,330 | 611 | 1,479 | 669 | 1,979 | 890
ROI | 44 | 4 | 20,556 | 801 | 37,362 | 1,240 | 685,100 | 17,308 | 1,420,115 | 33,678 | 1,590,540 | 36,319 | 6,650,803 | 152,671 | 7,394,078 | 167,194 | 9,895,810 | 222,597

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric).

Table 6-4 Probability (%) of making a decision to regulate or not regulate a chemical for TRDM^a,b^.

μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
| P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0) | P(D=1) | P(D=0)
PPI | <0.1 | 43.1 | 1.1 | 10.1 | 3.0 | 4.7 | 20.5 | 26.6 | 35.4 | 13.0 | 56.9 | 1.1 | 60.8 | 2.1 | 73.4 | 2.1 | 79.5 | 0.1
ETAP | <0.1 | 37.0 | 0.3 | 5.3 | 1.1 | 2.0 | 9.6 | 13.9 | 21.9 | 5.3 | 47.4 | 0.2 | 49.1 | 0.5 | 61.3 | 0.4 | 75.4 | 0.0129
THHA | <0.1 | 39.8 | 0.5 | 7.0 | 1.8 | 3.2 | 14.5 | 19.3 | 27.9 | 8.3 | 52.8 | 0.5 | 54.7 | 1.0 | 67.2 | 0.9 | 76.7 | 0.0394

a D=1 indicates a decision to regulate, and D=0 denotes a decision not to regulate.

b Partial perfect information (PPI) assumes perfect knowledge of μ_tox_

## 6.2 SENSITIVITY ANALYSES

The baseline scenarios presented in Section 6.1 partitioned the 1,578 chemical exposure datasets from SHEDS-HT into the nine domains shown in Figure 5-2, based on cross-classification of tertiles of μ_exp_ and σ_exp_, thereby allowing an assessment of VOI for lower and higher average exposures and lower and higher variation in population exposure. This analysis was conducted under the assumption that the adverse health outcome has an annualized economic valuation of $10K per case, the cost of exposure mitigation action is similar to EPA estimates for controlling key air pollutants, and that essentially the entire U.S. population is exposed to the chemical of interest. Recognizing that different chemicals will lead to different adverse health outcomes, require different exposure mitigation actions, and affect the larger or smaller fraction of the general population, a series of sensitivity analyses (i.e., sensitivity analysis scenarios) is provided to illustrate the effects of changes in these parameters. Detailed results of the sensitivity analysis scenarios are presented primarily for Baseline Scenario 5, with results for other scenarios included in the supplementary material.

### 6.2.1 EFFECT OF QUALITY OF EXPOSURE INFORMATION

Because of the high degree of variability in exposure (as reflected by both μ_exp_ and σ_exp_) across chemicals within each of these domains, there exists considerable uncertainty about exposure to untested chemicals which is not reduced by toxicity testing (recall that variability in mean exposure is used as a proxy for uncertainty in exposure for chemicals lacking population exposure data). To evaluate the impact of more precise prior information on chemical exposure, each of the nine exposure domains in the baseline analysis is subdivided into nine sub-domains. This results in a total of 81 sub-domains within which the variation in exposure is substantially less than in the baseline analysis which involved only nine domains (see Figure 6-4). From a practical perspective, the creation of additional sub-domains from the original nine domains corresponds to having some prior knowledge about the actual levels of population exposure to the specific chemical of interest.

Figure 6-5 identifies exposure domains - or additional scenarios - where ENBS values for ETAP are positive (in light blue) or negative (in orange), under the nine baseline scenarios and a sensitivity analysis with 81 additional scenarios, respectively, for the BRDM. These results indicate that μ_exp_ has a greater impact on whether ENBS_ETAP_ is positive or negative than does σ_exp_. It is also worth noting that one (11%) of the nine exposure scenarios in the baseline scenarios yields negative ENBS_ETAP_ values, whereas ten (12%) of 81 additional scenarios in the sensitivity analysis results in negative ENBS_ETAP_ values. Similar results are observed for THHA (Figure 6-6) where four (44%) baseline scenarios produce positive ENBS_THHA_ values, and 38 (47%) of the additional scenarios in the sensitivity analyses produce positive results.

Further comparison of the 81 sensitivity analysis scenarios indicates that ETAP produced greater EVDSI, ENBS, and ROI values than THHA in all scenarios where at least one of these two toxicity testing and assessment processes had positive values for all three of these VOI metrics (see Supplementary Table 6.2.1 BRDM). These results provide further support for the use of ETAP in preference to THHA for chemicals for which exposure estimates are available, but do not have repeated dose toxicity studies or human evidence suitable for use as a POD and reference value derivation.

Results for the TRDM are depicted in Figure 6-7, where the regions in blue represent cases where ENBS_ETAP_ is greater than ENBS_THHA_, regions in pink correspond to cases where ENBS_THHA_ is greater than ENBS_ETAP_, and regions in grey reflect cases in which no additional toxicity testing is required. In the Baseline Scenarios 2 to 9, ETAP is the preferred toxicity testing approach in terms of EVDSI, ENBS, and ROI. When the baseline scenarios are further partitioned, there are 12 additional sensitivity analysis scenarios (15%) in which no further testing is required, three (4%) additional scenarios where ENBS_THHA_ > ENBS_ETAP_, and 66 (81%) additional sensitivity analysis scenarios with ENBS_ETAP_ > ENBS_THHA_. These results indicate that knowing that both μ_exp_ and σ_exp_ are large (or small) with relatively high certainty may be sufficient for the TRDM to make a decision. It may also be noted that while two sensitivity analysis scenarios produced greater ENBS_THHA_ values, ROI_ETAP_ is always greater than ROI_THHA_ (see Supplementary Table 6.2.1 TRDM).

Figure 6-4 Mean (μ_exp_) and variability (σ_exp_) of exposure data for 1,578 chemicals in SHEDS-HT. (A) Red lines represent the nine domains to characterize the baseline scenarios. The green lines further partition each baseline scenario into an additional 3×3=9 sub-domains, creating a total of 81 domains. (B) Exposure data for the middle tertiles of μ_exp_ and σ_exp_ (Baseline Scenario 5) further partitioned into 3×3 sub-domains to parameterize the sensitivity analysis scenarios. For A and B, individual exposure datapoints are represented by black circles; domain means are represented by solid purple squares.

Figure 6 4. Mean (μexp) and variability (σexp) of exposure data for 1,578 chemicals in SHEDS-HT. (A) Red lines represent the nine domains to characterize the baseline scenarios. The green lines further partition each baseline scenario into an additional 3×3=9 sub-domains, creating a total of 81 domains. (B) Exposure data for the middle tertiles of μexp and σexp (Baseline Scenario 5) further partitioned into 3×3 sub-domains to parameterize the sensitivity analysis scenarios. For A and B, individual exposure datapoints are represented by black circles; domain means are represented by solid purple squares.

Figure 6-5 ENBS_ETAP_ for BRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in light blue indicate ENBS values are positive for ETAP. The regions in orange indicate ENBS values are negative for ETAP.

Figure 6 5. ENBSETAP for BRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in light blue indicate ENBS values are positive for ETAP. The regions in orange indicate ENBS values are negative for ETAP.

Figure 6-6 ENBS_THHA_ for BRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in light blue indicate ENBS values are positive for THHA. The regions in orange indicate ENBS values are negative for THHA.

Figure 6 6. ENBSTHHA for BRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in light blue indicate ENBS values are positive for THHA. The regions in orange indicate ENBS values are negative for THHA.

Figure 6-7 Comparison of ENBS values for ETAP and THHA for TRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in blue indicate ENBS_ETAP_ is greater than ENBS_THHA_; the regions in pink indicate ENBS_ETAP_ is less than ENBS_THHA_; grey regions denote scenarios in which no additional testing is required.

Figure 6 7. Comparison of ENBS values for ETAP and THHA for TRDM under (A) baseline scenarios with exposure information partitioned into 3×3 domains, and (B) sensitivity analysis scenarios with exposure information partitioned into 9×9 domains. The regions (scenarios) in blue indicate ENBSETAP is greater than ENBSTHHA; the regions in pink indicate ENBSETAP is less than ENBSTHHA; grey regions denote scenarios in which no additional testing is required.

### 6.2.2 EFFECT OF ADVERSE HEALTH OUTCOME AND COST OF CONTROL

As discussed in Section 5.3.1, health cost valuations may differ substantially, depending on the adverse health outcome of interest. Similarly, the annual cost of control can vary considerably, depending on the physicochemical properties, the toxicity, and the exposure pathways for that chemical. To explore the effect of the valuation of adverse health outcomes and the cost of control, a series of sensitivity analyses scenarios was evaluated varying these two cost parameters.

Table 6-5 summarizes the results of the VOI analysis for the BRDM under the conditions of Baseline Scenario 5^21^, but with changes in the annualized health cost (AHC) and annualized control cost (ACC). When the AHC is increased from $10K to $110K and with the ACC_max_ fixed at $23.1B, the ORE is increased to 100%. This leads to substantially increased CODs for both ETAP and THHA given the opportunity loss in health cost reduction while waiting for the additional toxicity data to make a decision. In particular, COD_ETAP_ is increased to $159B from $12B, while the CoD_THHA_ is increased to $2.1T from $169B. This results in EVDSI, ENBS, and ROI for both ETAP and THHA being negative, similar to the situation encountered in Baseline Scenario 9 from the baseline analysis. When the AHC is reduced to $1K, the reduction in ORE - with a concomitant reduction in CODs - results in positive values of EVDSI, ENBS, and ROI for the THHA (these values remain positive for ETAP as well). However, as these same metrics are larger for the ETAP, the BRDM would still prefer ETAP compared with the THHA. These results indicate that as the ratio of AHC-to-ACC_max_ increases, the ORE also increases, as does COD since the benefits of cost-effective exposure mitigation have been delayed.

It may be noted that a reduction in ACC_max_ has a qualitatively similar effect on VOI as an increase in AHC. For example, when the ACC_max_ is reduced from $23.1B to $578M (while keeping AHC fixed at $10K), both the ORE and EV|CI increase. As was observed when the AHC increased from $10K to $110K, this change results in negative EVDSI, ENBS, and ROI values for both ETAP and THHA.

As the TRDM does not consider the cost of control, changing the control cost does not affect the resulting VOI analysis (Table 6-5). This also implies that changes in EV|CI, EVIPPI, EVISI, COD, and EVDSI values are proportional to the change in AHC, with ETAP remaining the preferred testing and assessment strategy for the TRDM (See Supplementary Table 6.2.2 for further details).

Table 6-5 Sensitivity analysis scenarios of changing the valuation of annualized health cost (AHC) and annualized maximum control cost (ACC_max_) under Baseline Scenario 5 (μ_exp_=medium, σ_exp_=medium). (A): BRDM, and (B): TRDM^a^.

A. VOI analysis results under benefit-risk decision-making
ACC_max_ | $23.1B | | | | | | $578M
AHC | $1K | | $10K | | $110K | | $10K
ORE | 0 | | 78 | | 100 | | 100
EV\|CI ($B) | 45 | | 293 | | 1,276 | | 101
EVIPPI ($B) | 17 | | 154 | | 150 | | 3
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 12 | 15 | 133 | 143 | 112 | 129 | 2 | 3
CoD ($B) | 1 | 8 | 12 | 169 | 159 | 2,147 | 15 | 199
EVDSI ($B) | 12 | 6 | 121 | −26 | −48 | −2,017 | −13 | −196
ENBS ($B) | 12 | 6 | 121 | −26 | −48 | −2,017 | −13 | −196
ROI | 59,026 | 1,563 | 603,877 | −6,478 | −237,645 | −504,327 | −63,327 | −49,013

B. VOI analysis results under target-risk decision-making
AHC | $1K | | $10K | | $110K
EV\|CI ($B) | 45 | | 446 | | 4,903
EVIPPI ($B) | 32 | | 323 | | 3,549
| ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 30 | 31 | 297 | 314 | 3,263 | 3,458
CoD ($B) | 1 | 18 | 13 | 180 | 139 | 1,976
EVDSI ($B) | 28 | 13 | 284 | 135 | 3,124 | 1,482
ENBS ($B) | 28 | 13 | 284 | 135 | 3,124 | 1,482
ROI | 142,011 | 3,367 | 1,420,115 | 33,678 | 15,621,276 | 370,469

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric)

### 6.2.3 EFFECT OF TOXICITY TESTING AND ASSESSMENT DURATION AND TIME HORIZON

The overall time frame for completing the toxicity testing and the human health assessment can vary significantly depending on a number of factors such as the study review processes and assessment complexity. The baseline scenarios rely on estimates that the THHA requires 8 years from the start of toxicity testing to reaching a regulatory decision. This timeline was based on observations that the traditional two-year rodent bioassay takes an average of 4 years to complete, and the typical human health assessment process is estimated to take an additional 4 years. In the sensitivity analysis scenarios, additional time frames of 6- and 14-years were considered. Table 6-6 summarizes the results of the VOI analysis for the BRDM and the TRDM under Baseline Scenario 5, but with considerations for the different THHA timeframes. Given that the amount of uncertainty reduction remains the same, changes in assessment duration only affect the cost of delay (COD) and other VOI metrics that incorporate COD. When the THHA takes 14 years, the COD is increased by 95% when compared to the baseline scenario; this increase in COD resulted in reduced values of EVDSI, ENBS, and ROI for the BRDM. On the other hand, when the THHA assessment duration is reduced to 6 years, the corresponding COD is reduced by 30%, leading to increased EVDSI, ENBS, and ROI values. Similar observations can be made for the TRDM. The 14-year assessment timeframe led to a 53% increase in the COD, and a 21% reduction in the COD for the 6-year timeframe, when compared against an assessment duration of 8-years. In all 18 baseline scenarios for both the BRDM and TRDM, ETAP remained the preferred testing strategy, even when the THHA timeline is reduced to the minimum feasible duration of 6 years.

It may also be possible that ETAP could encounter unexpected delays that would extend the average 6-month timeframe for completion^22^. Additional sensitivity analyses assuming 1-year and 2-year timeframes for ETAP showed an increase in the CoD of 98% and 286%, respectively (Table 6-6), When comparing with THHA under the most favorable 6-year timeframe with ETAP under the least favorable 2-year timeframe, there were two scenarios for the TRDM (Scenarios 1 and 2, where the μ_exp_ was low and σ_exp_ was either low or medium) in which THHA was preferred over ETAP using ENBS. For the BRDM, ETAP demonstrated greater VOI than THHA in all nine scenarios. (Full details of the sensitivity analysis of assessment duration are provided in Supplementary Table 6.2.3 A).

An extended time horizon beyond 20 years may also be considered, thereby accounting for societal benefits that may continue to accrue after that time. To investigate the impact of extending the time horizon, 40-year and 75-year time horizons were also considered. For the BRDM, ETAP was preferred in all nine scenarios using delay-adjusted VOI metrics under both of these extended time horizons. For the TRDM, on the other hand, Scenarios 1 and 2 (low μ_exp_ and low-to-medium σ_exp_) preferred THHA based on ENBS under the 40-year time horizon, and Scenarios 1, 2, and 3 (low σ_exp_) preferred THHA under the 75-year time horizon. For the BRDM, the initial opportunity loss of delayed action reflected in the COD may be the driving factor in preferring ETAP over the THHA, despite the longer time horizon allowing the benefit of THHA to accrue for a greater period of time. For the TRDM, longer time horizons benefit THHA in scenarios where ETAP has difficulty concluding that a chemical requires a regulatory action (i.e., in scenarios where the risk is low and difficult to quantify with sufficient precision to decide). (Full details of the sensitivity analysis of an extended time horizon are provided in Supplementary Table 6.2.3 B).

It should also be noted that due to discounting of costs and benefits back to their net present value in VOI analysis, benefits realized far in the future are less valuable than benefits realized in the near term. In particular, under the assumption that it takes 10 years to implement a regulatory decision with THHA (8 years to collect and process information, and 2 years to implement a regulatory decision), 39% of total future benefits would be realized within a 20-year time horizon. Similarly, 77% and 96%, respectively, of total future benefits would be realized within the extended timeframes of 40 or 75 years. (See Supplementary Table 6.2.3 C for further details.)

Table 6-6 Sensitivity analysis scenarios of changing the assessment duration under Baseline Scenario 5 (μ_exp_=medium, σ_exp_=medium). The baseline analysis is conducted using 8 years for THHA and 6 months for ETAP. (A): BRDM, and (B): TRDM^a^.

A. VOI analysis results under benefit-risk decision-making
ORE | 78
EV\|CI ($B) | 293
| THHA | | | ETAP
EVIPPI ($B) | 146 | | | 154
EVISI ($B) | 143 | | | 133
Timeframe | 6 Years | 8 Years | 14 Years | 0.5 Years | 1 Year | 2 Years
CoD ($B) | 92 | 132 | 258 | 12 | 24 | 47
EVDSI ($B) | 50 | 10 | −116 | 121 | 109 | 86
ENBS ($B) | 50 | 10 | −116 | 121 | 109 | 86
ROI | 12,546 | 2,570 | −28,880 | 603,877 | 544,557 | 430,172

B. VOI analysis results under target-risk decision-making
EV\|CI ($B) | 445,722
| THHA | | | ETAP
EVIPPI ($B) | 322,652 | | | 322,652
EVISI ($B) | 314,381 | | | 296,667
Timeframe | 6 Years | 8 Years | 14 Years | 0.5 Years | 1 Year | 2 Years
CoD ($B) | 141 | 180 | 275 | 13 | 25 | 49
EVDSI ($B) | 173 | 135 | 39 | 284 | 272 | 248
ENBS ($B) | 173 | 135 | 39 | 284 | 272 | 248
ROI | 43,321 | 33,678 | 9,804 | 1,420,115 | 1,358,420 | 1,239,456

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric).

### 6.2.4 EFFECT OF STUDY COST

In the baseline scenarios, the costs of performing ETAP and THHA were assumed to be $200K and $4M, respectively. To evaluate the impact of alternative assumptions about the cost of toxicity testing, additional sensitivity analyses were conducted with the costs for ETAP increased to $250K, while the cost of THHA is reduced to $1M. The results of sensitivity analyses with alternative toxicity testing cost assumptions are summarized in Table 6-7 for the 18 baseline scenarios represented by the nine exposure domains and two decision makers. With the EVDSI values in billions of dollars, the effect of alterative assumptions for study cost is minimal. Even in Scenario 1 where the EVDSI values for ETAP and TRDM were $9M and $19M, respectively, ETAP was preferred over THHA based on both the calculated ENBS and ROI values.

Table 6-7 Sensitivity analysis scenarios using an increased cost of ETAP ($250K) and a decreased cost of THHA ($1M)^a^. $200K for ETAP and $4M for THHA are used in the baseline scenarios.

A. VOI analysis results under benefit-risk decision-making
μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
ORE | 0 | | 0 | | 0 | | 52 | | 78 | | 88 | | 100 | | 100 | | 100
EV\|CI ($B) | 35 | | 71 | | 53 | | 187 | | 293 | | 326 | | 683 | | 718 | | 915
EVIPPI ($B) | 10 | | 24 | | 15 | | 113 | | 154 | | 146 | | 119 | | 122 | | 74
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 7 | 8 | 18 | 21 | 11 | 12 | 98 | 105 | 133 | 143 | 126 | 135 | 86 | 101 | 88 | 103 | 47 | 59
CoD ($B) | 0.3 | 5 | 1 | 12 | 0 | 7 | 6 | 85 | 12 | 169 | 12 | 172 | 65 | 876 | 70 | 952 | 100 | 1,342
EVDSI ($B) | 6 | 3 | 18 | 9 | 10 | 5 | 92 | 20 | 121 | −26 | 113 | −36 | 22 | −775 | 17 | −849 | −53 | −1,283
ENBS ($B) | 6 | 3 | 18 | 9 | 10 | 5 | 92 | 20 | 121 | −26 | 113 | −36 | 22 | −775 | 17 | −849 | −53 | −1,283
ROI | 25,711 | 3,426 | 70,095 | 8,909 | 40,719 | 5,313 | 369,335 | 20,187 | 483,103 | −25,908 | 453,291 | −36,494 | 86,191 | −775,118 | 69,355 | −848,861 | −210,173 | −1,283,470

B. VOI analysis results under target-risk decision-making
μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
EV\|CI ($B) | 35 | | 71 | | 53 | | 231 | | 446 | | 492 | | 2,115 | | 2,281 | | 3,205
EVIPPI ($B) | 0.2 | | 14 | | 17 | | 170 | | 323 | | 342 | | 1,443 | | 1,566 | | 2,086
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 0.01 | 0.04 | 4 | 7 | 8 | 12 | 143 | 162 | 297 | 314 | 332 | 339 | 1,389 | 1,425 | 1,545 | 1,561 | 2,067 | 2,078
CoD ($B) | 0.00 | 0.03 | 0.2 | 4 | 0.3 | 7 | 6 | 92 | 13 | 180 | 14 | 194 | 59 | 814 | 66 | 892 | 88 | 1,187
EVDSI ($B) | 0.01 | 0.02 | 4 | 3 | 7 | 5 | 137 | 69 | 284 | 135 | 318 | 145 | 1,330 | 611 | 1,479 | 669 | 1,979 | 890
ENBS($B) | 0.01 | 0.02 | 4 | 3 | 7 | 5 | 137 | 69 | 284 | 135 | 318 | 145 | 1,330 | 611 | 1,479 | 669 | 1,979 | 890
ROI | 35 | 18 | 16,443 | 3,208 | 29,891 | 4,963 | 548,079 | 69,234 | 1,136,091 | 134,715 | 1,272,431 | 145,278 | 5,320,643 | 610,688 | 5,915,263 | 668,781 | 7,916,647 | 890,393

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric)

### 6.2.5 EFFECT OF AFFECTED POPULATION SIZE

In the baseline scenarios, the affected population size was assumed to be N=330M, representing the situation in which essentially 100% of the U.S. population is exposed to the chemical of interest. To investigate the impacts associated with only a subset of the population being exposed, while the cost of control remains the same, two sensitivity analysis scenarios are provided for population sizes in which 165M (50% of the U.S. population), and 33M (10%) people are exposed (Table 6-8) under Baseline Scenario 5^23^. For the BRDM with 50% of the population exposed, the ORE is reduced to 49% as the ratio AHC-to-ACC_max_ per capita is reduced by 50%. EV|CI is also reduced since the expected number of adverse events is reduced by 2-fold. In this case, the difference in the CODs for the two approaches is the dominant factor affecting EVDSI, ENBS, and ROI. The VOI metrics indicate that the ETAP performs better than the THHA; however, unlike the baseline scenario, THHA provides positive EVDSI, ENBS, and ROI values. Similar patterns are observed when N is further reduced to 33M people (10% of the U.S. population).

For the TRDM, reducing the population size is equivalent to a proportional reduction in ETHC. Hence, all VOI metrics that do not consider the COT are halved when the exposed population is reduced by 50% (N=165M), Similarly, these metrics are reduced by 10-fold when only 10% (N=33M) of the population is exposed.

Table 6-8 Sensitivity analysis scenarios of changing the affect population size N under Baseline Scenario 5 (μ_exp_=medium, σ_exp_=medium). The baseline analysis uses N=330M. (A): BRDM, and (B): TRDM^a^.

A. VOI analysis results under benefit-risk decision-making
Population size | 330M | | 165M | | 33M
ORE | 78 | | 49 | | 0
EV\|CI ($B) | 293 | | 189 | | 45
EVIPPI ($B) | 154 | | 106 | | 17
| ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 133 | 143 | 91 | 98 | 12 | 15
CoD ($B) | 12 | 169 | 5 | 75 | 1 | 8
EVDSI ($B) | 121 | −26 | 86 | 23 | 12 | 6
ENBS ($B) | 121 | −26 | 86 | 23 | 12 | 6
ROI | 603,877 | −6,478 | 429,503 | 5,761 | 59,026 | 1,563

B. VOI analysis results under target-risk decision-making
Population size | 330M | | 165M | | 33M
EV\|CI ($B) | 446 | | 223 | | 45
EVIPPI ($B) | 323 | | 161 | | 32
| ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 297 | 314 | 148 | 157 | 30 | 31
CoD ($B) | 13 | 180 | 6 | 90 | 1 | 18
EVDSI ($B) | 284 | 135 | 142 | 67 | 28 | 13
ENBS ($B) | 284 | 135 | 142 | 67 | 28 | 13
ROI | 1,420,115 | 33,678 | 710,057 | 16,839 | 142,011 | 3,367

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric)

### 6.2.6 EFFECT OF TARGET RISK LEVEL

In the baseline scenarios, the TRDM is concerned about risks that exceed a TRL of 10^−6^, a benchmark often used for carcinogens (EPA 2009). While EPA does not have a recommended TRL for non-cancer effects, higher risks may be inadvertently present, as reflected by the median estimated residual risks on the order of 10^−4^ for traditional RfDs (Chiu et al. 2018). The results of the VOI analysis using a TRL of 10^−4^ is summarized in Table 6-9. With this increase in the TRL, when both μ_exp_ and σ_exp_ are low (Baseline Scenario 1), q_U_ for the prior uncertainty distribution is below the TRL and the TRDM concludes that the chemical does not require regulatory action without collecting additional toxicity information. In the remaining sensitivity analysis scenarios, all VOI metrics except EV|CI are reduced for both ETAP and THHA, when compared to baseline scenarios, as it is now less likely that risk exceeds the higher TRL. In all scenarios included in this sensitivity analyses, the EVDSI, ENBS, and ROI favor ETAP over THHA.

Table 6-9 Sensitivity analysis scenarios of changing the TRL to 10^−4^ for TRDM^a,b^.

μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
EV\|CI ($B) | NA | | 71 | | 53 | | 231 | | 446 | | 492 | | 2,115 | | 2,281 | | 3,205
EVIPPI ($B) | NA | | 2 | | 3 | | 156 | | 304 | | 317 | | 1,382 | | 1,545 | | 2,035
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | NA | NA | 0.2 | 0.6 | 0.5 | 1.2 | 85 | 125 | 199 | 255 | 252 | 288 | 1,114 | 1,267 | 1,359 | 1,477 | 1,840 | 1,945
CoD ($B) | NA | NA | 0.01 | 0.3 | 0.02 | 0.7 | 4 | 72 | 8 | 146 | 11 | 164 | 47 | 724 | 58 | 844 | 78 | 1,112
EVDSI ($B) | NA | NA | 0.2 | 0.3 | 0.5 | 0.5 | 82 | 54 | 191 | 109 | 241 | 123 | 1,067 | 543 | 1,301 | 633 | 1,761 | 834
ENBS ($B) | NA | NA | 0.2 | 0.3 | 0.5 | 0.5 | 82 | 54 | 191 | 109 | 241 | 123 | 1,067 | 543 | 1,301 | 633 | 1,761 | 834
ROI | NA | NA | 991 | 65 | 2,385 | 129 | 407,931 | 13,412 | 954,215 | 27,329 | 1,206,013 | 30,800 | 5,332,748 | 135,748 | 6,503,564 | 158,274 | 8,806,044 | 208,416

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric)

b NA: not applicable, as the TRDM has sufficient information to make a decision based on the prior information without the need for additional toxicity testing. When q_05_ ≥ TRL, the risk is sufficiently high that a regulatory action is warranted; when q_95_ ≤ TRL, the risk is sufficiently low such that exposure mitigation action is not required.

### 6.2.7 DISCORDANCE AS A SOURCE OF ADDITIONAL UNCERTAINTY

There may be other sources of uncertainty that would possibly affect the VOI analyses presented in this paper. Because the ETAP and THHA incorporate quite distinct protocols, there may be a degree of discordance between these two approaches not explicitly incorporated in the baseline VOI analyses. Whereas the traditional two-year bioassay involves lifetime exposure to an environmental agent with in vivo integration across multiple toxicological systems, ETAP involves in vivo exposure over a period of five days, following which dose-responsive changes in the transcriptome are quantitatively examined.

Although the error associated with the concordance between the transcriptomic BMD values versus apical BMD values from the two-year bioassay was shown to be approximately equivalent to the combined inter-study variability, the root mean squared deviation (RMSD) between the estimated BMDs based on the short-term transcriptomic study and two-year bioassay may be used as a conservative upper bound of the additional uncertainty for ETAP due to discordance between these two tests. Based on the 14 chemicals for which BMDs for ETAP and traditional bioassay results are available, the RMSD is 0.567 (EPA 2024c), which translates to a discordance value of P_95_/P_50_=8.55. It may be noted that the additional discordance factor corresponds to the same 8-fold factor recommended by the IPCS in translating from subacute to chronic exposures (WHO 2017). With this additional source of uncertainty for the ETAP, σ_ETAP_ is 0.741 (compared to 0.442 in the baseline analysis).

Table 6-10 presents the results of the sensitivity analysis scenarios incorporating potential discordance between ETAP and THHA. For the BRDM, taking discordance into account reduces EVISI, EVDSI, ENBS, and ROI for ETAP. This is most apparent in scenarios in which μ_exp_ is high, where EVDSI_ETAP_ become negative in Baseline Scenario 7 and 8 (recall that EVDSI was negative in Baseline Scenario 9 in the baseline analysis). However, ETAP still provides superior EVDSI, ENBS, and ROI values in six scenarios, where either ETAP or THHA (or both) provided positive VOI metrics. For the TRDM, THHA produced greater EVDSI and ENBS values in Baseline Scenarios 1, 2 and 3. In Baseline Scenario 1, ETAP produced a negative ROI value while ROI_THHA_ was positive. These sensitivity analysis scenarios indicate that in the presence of greater posterior uncertainty about μ_tox_, ETAP is not uniformly superior to THHA, even when VOI is measured in terms of ROI. In particular, Baseline Scenario 1 represents a situation where the additional toxicity information provided by ETAP is insufficient to allow the TRDM to make a decision to regulate a chemical, and therefore the COT outweighs the benefits of uncertainty reduction.

Table 6-10 Sensitivity analysis scenarios on incorporating additional source of uncertainty for ETAP due to discordance with traditional bioassay results. (A): BRDM, and (B): TRDM^a^.

A. VOI analysis results under benefit-risk decision-making
μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
ORE | 0 | | 0 | | 0 | | 52 | | 78 | | 88 | | 100 | | 100 | | 100
EV\|CI ($B) | 35 | | 71 | | 53 | | 187 | | 293 | | 326 | | 683 | | 718 | | 915
EVIPPI ($B) | 10 | | 24 | | 15 | | 113 | | 154 | | 146 | | 119 | | 122 | | 74
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 4 | 8 | 13 | 21 | 7 | 12 | 83 | 105 | 112 | 143 | 106 | 135 | 59 | 101 | 59 | 103 | 27 | 59
CoD ($B) | 0.2 | 5 | 1 | 12 | 0 | 7 | 5 | 85 | 11 | 169 | 12 | 172 | 64 | 876 | 69 | 952 | 99 | 1,342
EVDSI ($B) | 4 | 3 | 13 | 9 | 7 | 5 | 78 | 20 | 101 | −26 | 94 | −36 | −5 | −775 | −10 | −849 | −72 | −1,283
ENBS ($B) | 4 | 3 | 13 | 9 | 7 | 5 | 78 | 20 | 101 | −26 | 94 | −36 | −5 | −775 | −10 | −849 | −72 | −1,283
ROI | 20,875 | 856 | 64,342 | 2,226 | 34,941 | 1,327 | 389,540 | 5,046 | 504,365 | −6,478 | 471,870 | −9,124 | −23,700 | −193,780 | −49,121 | −212,216 | −357,880 | −320,868

B. VOI analysis results under target-risk decision-making
μ_exp_ | Low | | | | | | Medium | | | | | | High
σ _exp_ | Low | | Medium | | High | | Low | | Medium | | High | | Low | | Medium | | High
Scenario | 1 | | 2 | | 3 | | 4 | | 5 | | 6 | | 7 | | 8 | | 9
EV\|CI ($B) | 35 | | 71 | | 53 | | 231 | | 446 | | 492 | | 2,115 | | 2,281 | | 3,205
EVIPPI ($B) | 0.2 | | 14 | | 17 | | 170 | | 323 | | 342 | | 1,443 | | 1,566 | | 2,086
| ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA | ETAP | THHA
EVISI ($B) | 0.00 | 0.04 | 1 | 7 | 2 | 12 | 85 | 162 | 227 | 314 | 307 | 339 | 1,257 | 1,425 | 1,466 | 1,561 | 2,014 | 2,078
CoD ($B) | 0.00 | 0.03 | 0.03 | 4 | 0.1 | 7 | 4 | 92 | 10 | 180 | 13 | 194 | 54 | 814 | 62 | 892 | 86 | 1,187
EVDSI ($B) | 0.00 | 0.02 | 1 | 3 | 2 | 5 | 82 | 69 | 217 | 135 | 294 | 145 | 1,204 | 611 | 1,403 | 669 | 1,928 | 890
ENBS ($B) | 0.00 | 0.02 | 1 | 3 | 2 | 5 | 82 | 69 | 217 | 135 | 294 | 145 | 1,204 | 611 | 1,403 | 669 | 1,928 | 890
ROI | −0.2 | 4 | 3,826 | 801 | 11,068 | 1,240 | 408,291 | 17,308 | 1,085,604 | 33,678 | 1,468,713 | 36,319 | 6,019,198 | 152,671 | 7,016,162 | 167,194 | 9,638,857 | 222,597

a EVDSI, ENBS, and ROI are shown with color gradation (min → zero → max, with darker shades of red and blue indicating larger negative and larger positive values, respectively, of the VOI metric).

21 Detailed results for remaining scenarios are provided in the supplemental material.

22 While the average production time for an ETAP has been 6 months, the Agency anticipates that ETAPs will be issued within 9 months of chemical procurement to issuance of the assessment. For those chemicals that meet the ETAP applicability domain, but for which orthogonal data suggests a change to the standard methods, the Agency has established an external peer review process that may impact the time to issue the assessment for those rare cases.

23 Detailed results for remaining scenarios are provided in the supplemental material.