# 5 PARAMETERIZATION OF VOI MODELS

Parameterization of the decision-making scenarios in the VOI analysis is informed, where possible, by realistic data on toxicity, exposure, chemical mitigation actions, health economics, and decision making. The parameterization is broken down into a core set of baseline scenarios and a complementary set of sensitivity analysis scenarios (Fig. 3-1). The core set of baseline scenarios reflect potential differences in exposure characteristics and decision contexts while the sensitivity analysis scenarios were developed to investigate potential impacts of varying other important parameters in the VOI analyses. The range in parameter values in both the baseline and sensitivity analysis scenarios were designed to evaluate potential differences in VOI across the diverse set of chemicals that could be candidates for human health assessment by ETAP or THHA.

## 5.1 TOXICOLOGICAL PARAMETERIZATION

### 5.1.1 PRIOR UNCERTAINTY IN TOXICITY

In order to apply the VOI framework discussed in Section 2, it is necessary to establish a prior distribution of uncertainty in chemical toxicity in the absence of any specific knowledge about the toxicity of the chemical to be tested. The original VOI framework used data previously considered by Krewski et al. (1993) on variation on the potency of the chemical carcinogens as well as data used by Chiu et al. (2018) on variation in toxicity reflected in distribution of PODs for non-cancer, critical effects. To characterize the prior distribution of chemical toxicity in this case study, we utilize data on 608 chemicals considered previously by Chiu et al. (2018). These chemicals include substances evaluated under the EPA Integrated Risk Information System (IRIS), the Office of Pesticide Programs (OPP), Superfund Regional Screening Levels (RSLs) programs, as well as substances evaluated by California EPA Office of Environmental Health Hazard Assessment. With more than one endpoint evaluated for many of these chemicals, there are a total of 1,522 chemical-endpoint combinations in this database. As indicated in Figure 5-1, the 1,522 chemicals and endpoints considered by Chiu et al. (2018) reflect a variety of subchronic and chronic toxicity (non-cancer) endpoints.^7^

The median human dose (HD_M_^I^) associated with an effect of magnitude (M) and population incidence (I) across the 1,522 chemicals and endpoints considered by Chiu et al. (2018) is H D_M_^50^ = using the average human body weight of 80kg (EPA 2011c), corresponding to a value of μ_tox_=log_10_(HD_M_^50^)=0.51. Excluding chemicals with extremely high potencies, such as 2,3,7,8-tetrachlorodibenzo-p-dioxin and those chemicals tested above the limit dose of 1,000 mg/kg-day, the distribution of toxic potency spans approximately 6 orders of magnitude (OM). Assuming this represents approximately 99.9% of the variation in the PODs for non-cancer endpoints expressed by these chemicals, the log_10_ prior uncertainty standard deviation in chemical toxicity of an untested chemical u^0^(μ_tox_) is given by 6/(2z_0.9995_)=6/6.58=0.912.

Information on σ_tox_, which is the logarithm of the geometric standard deviation [log_10_(GSD)] of human susceptibility, is provided by the International Programme on Chemical Safety (IPCS) [WHO (2017), Table 4.4]^8^. The value of σ_tox_ is calculated to be 0.424 using the midpoint of 5^th^ and 95^th^ percentiles (P_05_=0.151 and P_95_=0.697), with uncertainty about er_tox_ being u(σ_tox_)=0.166. Since σ_tox_ cannot be negative, the VOI framework currently integrates uncertainty distribution between ±6u(·) about the mean, u(σ_tox_) as σ_tox_/6=0.0706.

Figure 5-1 Overview of toxicological effect types represented by 1,522 chemicals and endpoints. [Reproduced from Chiu et al. (2018), Figure 5A, originally published in Environmental Health Perspectives, with permission from the authors.]

### 5.1.2 CONDITIONAL POSTERIOR UNCERTAINTY ABOUT μ_tox_ FOR THHA

In order to extrapolate the results of two-year rodent bioassays to humans, it is necessary to translate the value of μ_tox_ to an HED. This is done using the HD_M_^I^, as outlined by Chiu et al. (2018). In addition to providing a best estimate of the HED, the uncertainties associated with the various steps in this extrapolation need to be considered. As indicated in Table 5-1, key sources of uncertainty include variation among animals within a given bioassay, uncertainties in allometric scaling in extrapolating from animals to humans, and differences in toxicokinetics (TK) and toxicodynamics (TD) between animals and humans, after adjusting for differences in body weight.

The sources of uncertainty summarized in Table 5-1 are characterized by the ratio, P_95_/P_50_, of the 95^th^ to 50^th^ percentiles of the respective uncertainty distributions. Intra-study variation is reflected in the BMD/BMDL ratio. The BMDL is the lower confidence limit of the estimated BMD. As a result, toxicity tests with less uncertainty will result in the BMDL being closer to the BMD, and correspondingly smaller BMD/BMDL ratios. To estimate the uncertainty associated with the BMD values derived from animal bioassay, data from 584 two-year rodent bioassays are used to determine the distribution of BMD_10_/BMDL_10_ ratios (Sand et al. 2011), where BMD(L)_10_ corresponds to BMD(L) values associated with a benchmark response (BMR) of 10% extra risk. The mean BMD_10_/BMDL_10_ ratio across 584 datasets was 1.803 and is used as the estimated intra-study variability shown in Table 5-1. The uncertainty due to allometric scaling (1.235) is based on results reported by Chiu et al. (2018), and the uncertainty in differences in TK/TD between animals to humans (3.000), is taken from published work by the IPCS [WHO (2017), Table 4.3].

Table 5-1 Sources of uncertainty for two-year rodent bioassays in THHA

Source of Uncertainty | Uncertainty (P_95_/P_50_) | [Log_10_(P_95_/P_50_)]^2^
Intra-study (BMD/BMDL)^a^ | 1.803 | 0.066
Allometric scaling^b^ | 1.235 | 0.008
Animal-human TK/TD^c^ | 3.000 | 0.228
Total | | 0.302

a Calculated based on the distribution of 584 BMD_10_/BMDL_10_ ratios for rodent bioassays presented in Sand et al. (2011).

b Taken from Chiu et al. (2018).

c Taken from Table 4.3 in IPCS (WHO 2017).

Let HD denote the HD_M_^50^. Following Chiu and Slob (2015), the uncertainty standard deviation for HD using the three sources of uncertainty about HD in Table 5-2 can be obtained by first calculating the ratio P_95_/P_50_ for the HD as

(P_95_H D__)/(P_50_H D__) = 10^{Σ_i = 1_^3^ [log_10_ ((P_95 , i_)/(P_50 , i_))]^2^}^1 / 2^^ = 10^( 0.302 )^1 / 2^^ = 3.541 , (2)

and then converting the ratio to the GSD as

G S D_T H H A_ = ((P_95_H D__)/(P_50_H D__))^1 / 1.645^ = 2.157 . (3)

The sample standard deviation σ_B_ for the bioassay is obtained by taking the logarithm of the GSD, with

σ_T H H A_ = l o g_10_ (G S D_T H H A_) = 0.334 (4)

Under the assumption of lognormality in both the prior uncertainty in μ_tox_ and variability in the sample information, application of Bayesian updating leads to the conditional posterior uncertainty standard deviation of

u_μ_t o x__^T H H A^ = ((σ_B_^2^ + (u_μ_t o x__^0^)^2^)/(σ_B_^2^ + (u_μ_t o x__^0^)^2^))^(1)/(2)^ = ((0.334^2^ × 0.912^2^)/(0.334^2^ + 0.912^2^))^(1)/(2)^ = 0.313 . (5)

### 5.1.3 CONDITIONAL POSTERIOR UNCERTAINTY ABOUT μ_tox_ FOR ETAP

The information required to derive the posterior conditional uncertainty about μ_tox_ following a five-day transcriptomic study is summarized in Table 5-2. This source of uncertainty is gauged in terms of intra-study variability, estimated by the average of the transcriptomic BMD_10_/BMDL_10_ ratios for 14 chemicals for which both five-day in vivo transcriptomic and chronic rodent bioassay dose-response data are available and analyzed as described in the ETAP scientific support document (EPA 2024c; Gwinn et al. 2020)^9^. Since both the two-year bioassay and five-day transcriptomic studies are in vivo toxicity testing strategies using rodents, the uncertainty due to allometric scaling and animal-human TK/TD remains the same for both methods.

Table 5-2 Sources of uncertainty for five-day transcriptomic studies in ETAP

Source of Uncertainty | Uncertainty (P_95_/P_50_) | [Log_10_(P_95_/P_50_)]^2^
Intra-study (BMD/BMDL)^a^ | 3.476 | 0.293
Allometric scaling^b^ | 1.235 | 0.008
Animal-human TK/TD^c^ | 3.000 | 0.228
Total | | 0.529

a Calculated based on the distribution of 14 BMD_10_/BMDL_10_ ratios for ETAP considered by EPA (EPA 2023a).

b Taken from Chiu et al. (2018).

c Taken from Table 4.3 in IPCS (WHO 2017).

Using the VOI parameters in Table 5-2 and performing the same calculations presented in Section 5.1.2 for the bioassay, the sample standard deviation of the five-day transcriptomic studies in ETAP is obtained as

σ_E T A P_ = l o g_10_ (G S D_E T A P_) = 0.442 , (6)

with the posterior conditional uncertainty about μ_tox_ being

u^E T A P^ (μ_t o x_) = 0.398 . (7)

It should be noted that, for both methods, toxicity testing reduces the uncertainty in μ_tox_, but not σ_tox_, as the latter parameter reflects inter-individual variation in susceptibility in the target population.

## 5.2 EXPOSURE PARAMETERIZATION

In order to ensure that the case study reflects realistic chemical exposures, the EPA’s High-Throughput Stochastic Human Exposure and Dose Simulation Model (SHEDS-HT) (Isaacs et al. 2014) was used to obtain exposure estimates for 1,578 chemicals from the TSCA active inventory. Exposure estimates were generated for a simulated population of 10,000 individuals using published parameterizations of consumer products (Ring et al. 2019) and food contact pathways (Biryol et al. 2017; Ring et al. 2019).^10^

Although the majority of the U.S. population is expected to be exposed to most of these chemicals, the exposed population can be quite small for other chemicals. SHEDS-HT makes two key assumptions in its predictions of chemical exposures: first, the prevalence of any chemical within food contact materials (i.e., the fraction of foods contacting materials containing chemical) is assumed to be 100%; and second, the prevalence of any specific chemical within all products is assumed to be 100%, as the market penetration of any given product formulation is unknown. These two assumptions provide conservative estimates of exposure for a broad array of chemicals, but likely overestimating actual real-world exposures. It should be noted that these two routes do not cover all possible exposure pathways (excluding, for example, food chemicals such as food additives and contaminants). As such, the exposure profiles developed using SHEDS-HT may not reflect total exposure to the chemical of interest from all possible sources and routes. Nonetheless, SHEDS-HT does provide a rich source of exposure data spanning a broad range of chemical exposure profiles. As the VOI analyses focus on impacts on the exposed population, the logarithm (log_10_) of the geometric mean (GM) for exposed individuals across the 1,578 chemicals and the logarithm of the GSD averaged across chemicals are used as the μ_exp_ (−2.271) and σ_exp_ (0.493), respectively.^11^ In order to calibrate uncertainty about the true value of μ_exp_, the variation in mean exposure across chemicals, given by u(μ_exp_)=1.401, was used as a proxy indicator of uncertainty in μ_exp_, in much the same way as the uncertainty in μ_tox_ was gauged by variation in toxicity of chemicals that have been previously tested. Similarly, the uncertainty in the true value of σ_exp_ is given by u(μ_exp_)=0.183, calculated as the standard deviation of the values of the σ_exp_ across chemicals. As discussed in Section 5.1.1, u(μ_exp_) is set to σ_exp_/6=0.0305 to avoid negative σ_exp_ value in the VOI calculation.

Because of the extremely large variation in exposure estimates across all 1,578 chemicals from the SHEDS-HT model, using the entire dataset as the basis for gauging prior uncertainty in exposure would introduce substantial uncertainty into the VOI analysis that is not reduced by toxicity testing. Expecting that some prior information about exposure will be available for most chemicals based on intended use and other information, the SHEDS-HT dataset was partitioned into nine domains. The chemicals were first partitioned, into three tertiles based on their μ_exp_ values (representing low, medium, and high average exposure), with 526 (=1,578/3) chemicals in each level of average exposure. Chemicals were further sub-partitioned into three tertiles based on their σ_exp_ values (representing low, medium, and high variability in exposure). Each of the resulting 3×3=9 exposure domains contain approximately 175 (=526/3) chemicals.

For the ith domain (i=1,...,9), μ_exp,i_ and σ_exp,i_ are estimated by taking the means within the subgroup as summarized and represented graphically in Figure 5-2. The corresponding uncertainty standard deviations u(μ_exp,i_) and u(σ_exp,i_) are also summarized in Table 5-3.

Figure 5-2 Scatter plot showing μ_exp_ and σ_exp_ for the exposed population across 1,578 chemicals from SHEDS-HT. The exposure estimates are partitioned into nine domains by dividing μ_exp_ and σ_exp_ into tertiles (i.e., low/medium/high). The purple squares denote the average μ_exp,i_ and σ_exp,i_ for each partitioned domain.

Figure 5 2. Scatter plot showing μ_exp and σ_exp for the exposed population across 1,578 chemicals from SHEDS-HT. The exposure estimates are partitioned into nine domains by dividing μ_exp and σ_exp into tertiles (i.e., low/medium/high). The purple squares denote the average μ_(exp,i) and σ_(exp,i) for each partitioned domain.

Table 5-3 Exposure parameters for nine conditional exposure scenarios

μ_exp_ | Low | | | Medium | | | High
σ _exp_ | Low | Medium | High | Low | Medium | High | Low | Medium | High
Scenario | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9^a^
μ_exp,i_ | −4.419 | −4.180 | −4.438 | −2.358 | −2.175 | −2.469 | −1.439 | −1.357 | −1.282
u(μ_exp,i_) | 1.076 | 0.965 | 0.881 | 0.307 | 0.341 | 0.365 | 0.423 | 0.325 | 0.417
σ _exp,i_ | 0.517 | 0.780 | 0.927 | 0.399 | 0.473 | 0.748 | 0.463 | 0.482 | 0.609
u(σ_exp,i_) | 0.086 | 0.042 | 0.093 | 0.013 | 0.010 | 0.100 | 0.008 | 0.006 | 0.101

a μ(σ_exp,i_) is reduced to σ_exp,i_/6

## 5.3 OTHER PARAMETERS

The VOI analysis requires selecting parameters that govern not only the toxicity and exposure information on the range of chemicals for which the two toxicity testing and assessment processes may be applied, but also the economic valuation of various outcomes and timelines. This section summarizes the rest of the parameters used in the VOI analysis presented in Section 6.1.

### 5.3.1 ADVERSE HEALTH OUTCOME VALUATION

The economic value associated with adverse health outcomes varies widely with the severity of the outcome, including whether the outcome is acute or chronic, non-life-threatening or fatal, and irreversible or reversible. Health economists have estimated and applied a value of a statistical life (VSL) of $8.8M^12^ (EPA 2022b). Most valuations of non-fatal adverse health effects focus on direct medical costs, lost productivity, and direct non-medical costs such as education or transportation.^13^ In an international review of the economic costs associated with childhood disabilities, Shahat and Greco reported a range of annualized values from $450 to $69,500, corresponding to $36,000 to $5.6M over the course of an 80-year lifetime (Shahat and Greco 2021). While the range of valuations is informative, the lower values in this range may not be directly relevant in the U.S. context, because of the higher cost of the U.S. health system compared to other developed countries. Economic values have also been estimated for specific diseases in the U.S. including autism at $69,530 annually (Ganz 2007), asthma at $36,500 (Belova et al. 2020). Down syndrome at $15,311 (Peng et al. 2009), and pervasive developmental disorders at $10,538 (Peng et al. 2009), Buescher et al. (2014) estimated the annual costs (in 2011 dollars) for children with autism spectrum disorders (ASD) and intellectual disability at $86,000 - $107,000 annually (depending on age) and for children with ASD and no intellectual disability at $52,000 - $63,000. Although these examples do not constitute a systematic review of the literature on health effects valuations, they provide useful benchmarks for determining the range of economic values for adverse health outcomes to be used in the present VOI analysis.

In the previously published VOI analyses, Hagiwara et al. (2022) considered annualized valuations of $110,000 for a fatal outcome.^14^ Acute adverse health effects, such as a restricted airway event, were valued at $70 per occurrence^15^ (EPA 2013, 2021). Assuming an expected rate of occurrence of one event per week, this corresponds to an annualized cost of $2,600. Considering the range of valuations discussed above, values of $110,000, $10,000, and $1,000 are used in the present VOI analysis to capture the potentially broad range of adverse outcomes following exposure to an untested chemical. As the great majority (>98%) of the adverse health effects caused by the 1,522 chemicals and endpoints considered by Chiu et al. (2018) are not fatal, a value of $10,000 is used in the baseline scenarios in the analysis, with the other two values presented as sensitivity analyses (Section 6.2).

### 5.3.2 CONTROL COSTS

Control costs were evaluated that would capture both the high and low ends in the range of costs for a chemical that may be evaluated by ETAP. At the high end, the maximum annualized control cost, denoted by ACC_max_, for reducing emissions of key air pollutants in the United States was considered. EPA estimated an average annual control cost of $2.0B for individual air pollutants such as acid gas, mercury (Hg), particulate matter less than 2.5 microns in aerodynamic diameter (PM_2.5_), and sulfur dioxide (SO_2_) (EPA 2011b). Trends in emission rates demonstrated a reduction of 25% between 1990 and 2021 across the following seven key air pollutants: carbon monoxide (CO), ammonia (NH_3_), nitrogen oxides (NO_x_), PM_2.5_, PM_10_, SO_2_, and volatile organic compounds (VOCs) (EPA 2022). As the cost of exposure reduction is expected to increase as exposure is reduced to lower and lower levels, the annualized control is modelled as

A C C_k_ = A C C_m a x_ ((10^η k^ - 1)/(10^η^ - 1)) . (8)

where 0 ≤ k ≤ 1 denotes the proportionate reduction in mean exposure and η > 0 governs the steepness of this relationship. Setting η=1 and solving Eq. (8) for ACC_max_ gives $23.1B, which is used as the default value for this cost parameter.

At the lower end of the range of control costs, a recent evaluation of the costs of chemical restriction proposals between January 2010 to May 2020 under the European Union's Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) indicated an annualized total expenditure of €1.7B across all the proposals (ECHA 2021). The annualized control cost associated with each of the 33 risk management programs considered in this evaluation are shown in Figure 5-3. Annualized control cost ranges from a low of €12K associated with substitution of trifluoroacetate salts in spray products to a high of €955M for reformulation and compliance cost for intentionally added microplastics.^16^ The mean and median control cost across all chemical control programs included in this program were €53.3M and €6M, respectively, corresponding to $50.6M and $5.7M, based on average 2022 exchange rates. Excluding those programs with zero cost, the mean and median values increased to €60.7M ($57.6M) and €17.6M ($16.7M), respectively. Based on the diverse set of chemical control programs, a control cost using ACC_max_ of $578M (using Eq. (8) with a $50M ACC at 25% reduction and η=1) is included for the sensitivity analysis in addition to the $23.1B used for the baseline scenarios discussed above.

Figure 5-3 Boxplot of annualized control cost associated with 33 risk management programs under the REACH registration (in €M). The overall median and mean control costs are €6M and €53.3M, respectively.

Figure 5 3.Boxplot of annualized control cost associated with 33 risk management programs under the REACH registration (in €M). The overall median and mean control costs are €6M and €53.3M, respectively.

### 5.3.3 AFFECTED POPULATION SIZE

For the baseline scenarios, the size of the affected population is set to be N=330M people, representing essentially the entire U.S. population. To investigate the impacts associated with only a subset of the population being exposed, two sensitivity analysis scenarios were evaluated for population sizes in which 165M (50% of the U.S. population), and 33M (10%) people are exposed.

### 5.3.4 DISCOUNT RATE

To account for the fact that costs and benefits realized in the future are of less economic value than those realized immediately, a discount rate of r=5% is applied in the calculation of the TSC to standardize all costs and benefits to their net present values at the beginning of the time horizon. The present case study employed a discount rate of 5%, consistent with the recommendation of the EPA Science Advisory Board (SAB)(EPA 2004) and current economic conditions. Other discount rates could also be considered, such as the value of 3% subsequently recommended by the 2010 EPA economic analysis guidelines (EPA 2010). Sensitivity analyses previously conducted by Hagiwara et al. (2022) using discount rates of 3, 5, and 7% showed that choice of discount rate did not dramatically alter VOI.

### 5.3.5 TOXICITY TESTING AND ASSESSMENT DURATION

The baseline analysis relies on estimates that the THHA requires 8 years from the start of toxicity testing to reaching a regulatory decision. This timeline was based on observations that the traditional two-year rodent bioassay takes an average of 4 years to complete (Faustman and Omenn 2015; NTP 1996; Pastoor and Stevens 2005), and the typical human health assessment process is estimated to take an additional 4 years (Krewski et al. 2020). To investigate the effect of shortening the testing and assessment time of THHA, a sensitivity analysis scenario was considered that reduces the human health assessment process to 2 years, thereby encompassing a 6-year timeframe for testing and decision making. The 2-year timeframe is consistent with the targets for implementation of the streamlined IRIS assessment process for less challenging assessments^17^. The effects of a longer time frame for THHA were also considered. The NTP routinely establishes and conducts high quality toxicity testing studies on chemicals selected for analysis via a nomination process. For the most recent chemicals tested that evaluated effects of chronic exposure to adult animals as the primary focus, the completion time from the start of the 2-year bioassay and issuance of the report was on average 8 years, with a standard deviation of approximately 1 year, and with a maximum duration of 9.5 years^18^. Based on this information, sensitivity analysis was performed on the approximate maximum of 10 years for toxicity testing and the 4 years required to complete the assessment with the total time resulting in a delay in decision making as long as 14 years with THHA.

For the ETAP, the baseline analysis assumes that the studies and human health assessment can be completed in 6 months^19^. It is possible that delays may be encountered when performing an ETAP due to issues such as chemical purity, stability, or selecting the appropriate dose range. To investigate the effects of lengthening the time required for testing and developing the human health assessment for ETAP, additional sensitivity analyses were performed assuming 1-year and 2-year timeframes.

### 5.3.6 TIME HORIZON

The time horizon, denoted by TH, over which the TSC is calculated, is set to 20 years in the baseline scenarios since it is a time frame commonly used in health economics. In sensitivity analysis scenarios, additional time horizons of 40 years and 75 years were considered for evaluating impacts of health effects that may be encountered by the exposed population over a generation or over a lifetime.

### 5.3.7 STUDY AND ASSESSMENT COSTS

In the baseline scenarios, the costs of performing a chronic rodent bioassay was estimated to be $4M and derived from multiple sources (Faustman and Omenn 2015; NTP 1996; Pastoor and Stevens 2005). To evaluate the impact of alternative assumptions about the cost of toxicity testing, an additional sensitivity analysis was conducted using different study costs. Bottini and Hartung estimated the cost of a traditional chronic rodent bioassay to be €780K, or $845K (Bottini and Hartung 2009). Typically, a traditional chronic bioassay is conducted following a subchronic or other short-term study to set the appropriate dose range. When combined with a subchronic toxicity study (€116K, or $126K) or a short-term study (€49K, or $53K), the total cost of testing for THHA may be between $898K and $971K. For the sensitivity analysis, the cost of THHA was reduced to $1M.

For the ETAP, the five-day in vivo transcriptomic study and ETAP process currently costs approximately $200,000 for the baseline scenario^20^. The most variable cost component of an ETAP assessment is chemical procurement, which can range from less than $5K to over $50K. In the sensitivity analysis, the effect of changing the study cost was investigated by assuming that the cost associated with ETAP is increased to $250K.

Although it is recognized that there are labor costs associated with the review of available data and with the composition and issuance of the human health assessment, in the absence of authoritative quantitative information on the relevant average labor costs, the cost associated with development of the traditional human health assessment is presumed to be $0 for the purposes of the case study. In the case of ETAP, the assessment labor costs are expected to be significantly less than with THHA due to the ETAP standardized reporting format and significantly shorter time required for data review and quality assurance steps, which would impact the VOI to favor ETAP.

### 5.3.8 ADDITIONAL CONSIDERATIONS FOR TARGET-RISK DECISION-MAKING

The decision rule for the TRDM requires specification of the q_L_ and q_U_ to determine whether the chemical of interest warrants exposure mitigation action. In the present analysis, the q_L_ and q_U_ are set to 5% and 95%, respectively. Unlike the BRDM, who considers the cost of exposure reduction, leading to an optimal reduction in exposure, decisions taken by the TRDM are driven by achieving the TRL regardless of exposure reduction cost. Acknowledging that it is not always possible to eliminate exposure, it is assumed that the TRDM reduces the GM of the population exposure by 90% when exposure mitigation is deemed necessary (Hagiwara et al. 2022). While EPA does not have a recommended TRL for non-cancer effects, a value of 10^−6^ is often used for cancer-related effects (EPA 2009). The baseline scenarios were conducted using a TRL=10^−6^. For the sensitivity analysis, a TRL=10^−4^ was also considered. Chiu et al. (2018) noted that the median residual risk at the traditional reference dose (RfD) for most of the 1,522 chemicals and endpoints included in their analysis is less than 0.01%.

A summary of the parameter values governing prior information on toxicity and exposure, toxicity testing and assessment, economic valuation of health impact, and decision making contexts used in the baseline scenarios of ETAP versus THHA presented in Section 6.1 is given in Table 5-4. Results from the variations in these parameter values were used in the sensitivity analyses presented in Section 6.2.

Table 5-4 Summary of parameter values used in the baseline VOI analysis of ETAP versus THHA.

Parameter | Description | Value
Toxicity and exposure information
μ _tox_ | log_10_ ( H D_M_^50^ ) | 0.51 (log_10_-mg/kg-day)
u(μ_tox_) | Uncertainty standard deviation about μ_tox_ | 0.91 (log_10_-mg/kg-day)
σ _tox_ | log_10_(GSD) for human susceptibility | 0.424 (unitless)
u(σ_tox_) | Uncertainty standard deviation about σ_tox_ | 0.07 (unitless)
μ _exp_ | log_10_(GM) for population exposure | −4.42 ~ −1.28 (log_10_-mg/kg-day)
u(μ_exp_) | Uncertainty standard deviation about μ_exp_ | 0.31~1.08 (log_10_-mg/kg-day)
σ _exp_ | log_10_(GSD) for population exposure | 0.40~0.93 (unitless)
u(σ_exp_) | Uncertainty standard deviation about σ_exp_ | 0.006~0.10 (unitless)
Toxicity testing and assessment process information
σ _ETAP_ | Sampling variability for ETAP | 0.442 (unitless)
COT_ETAP_ | Cost of running ETAP | $200,000
t _ETAP_ | Time required to obtain ETAP information | 6 months
σ _THHA_ | Sampling variability for THHA | 0.334 (unitless)
COT_THHA_ | Cost of running THHA | $4M
t _THHA_ | Time required to obtain THHA information | 8 years
Economic valuation
N | Affected population size | 330 million persons
t _imp_ | Time required to implement regulation | 2 years
TH | Time horizon | 20 years
AHC | Annualized health cost | $10,000
ACC_max_ | Maximum annualized control cost | $23.1B
η | Steepness parameter for control cost function | 1 (unitless)
r | Discount rate | 5%
TRDM specific information
q_L_ | Lower quantile for uncertainty distribution about risk | 5^th^ percentile
q_U_ | Upper quantile for uncertainty distribution about risk | 95^th^ percentile
TRL | Target risk level | 10^−6^ (unitless)
k _TRDM_ | Proportion of exposure reduction | 90%

7 Although a subset of the chemicals considered by Chiu et al. (2018) may also increase cancer risk, only the non-cancer outcomes were considered in their analysis of this dataset.

8 IPCS obtained the variability in human susceptibility by combining toxicokinetic (TK) and toxicodynamic (TD) variability in equipotent dose distributions for humans.

9 The primary data from the Gwinn et al., 2020 study that was utilized for the analysis are accessible online at: https://cebs.niehs.nih.gov/cebs/paper/14731. The transcriptomic BMD analysis files from the ETAP scientific support document are available at: https://clowder.edap-cluster.com/datasets/660ad607e4b063812d7Q0fe6

10 Included in these 1,578 chemicals were 665 chemicals present in consumer products, 625 chemicals in food contact materials, and 288 chemicals present in both consumer products and food contact materials. The aggregated population exposure estimates were generated using SHEDS-HT version v.0.1.8.

11 This calculation assumes a lognormal distribution of exposure within the exposed population, so that the GMs and GSDs in SHEDS-HT can be converted to logarithmic exposures to be used within the VOI framework.

12 VSL given in 2016 USD, based on a base value of $7.4M in 2006 USD (EPA 2022a).

13 These estimates are based on costs of illness rather than the willingness to pay measure of value for changes in health risks that focus on changes in individual well-being, referred to as welfare or utility. For more information, consult EPA’s Guidelines for Preparing Economic Analyses (EPA 2010).

14 The value of $110,000 does not correspond to the value of a single life year, but rather to the annualized value of a risk reduction action that is assumed to occur over an 80-year period, based on the VSL of $8.8M used by EPA.

15 This estimate is based on wiliingness-to-pay to avoid a single asthma attack.

16 Several control programs with zero cost, such as an industry decision to move away from use of long-chain perfluorinated substances, are excluded from this range.

17 Refers to GAO Report GAO-12-42 assessing the EPA’s 2009 revisions to the IRIS program, accessible via https://www.gao.gov/products/gao-12-42.

18 Time frame estimates were derived from the time elapsed between the start of dosing for the two-year rodent bioassay and the publication date of the technical reports for TR-585 through TR-594 published between September 2014 and January 2019. Estimates do not include project scoping, pre-study evaluations, or the 90-day subchronic study. For more information on NTP technical reports, visit https://ntp.niehs.nih.gov/data/tr.

19 While the average production time for an ETAP has been 6 months, the Agency anticipates that ETAPs will be issued within 9 months of chemical procurement to issuance of the assessment. For those chemicals that meet the ETAP applicability domain, but for which orthogonal data suggests a change to the standard methods, the Agency has established an external peer review process that may impact the time to issue the assessment for those rare cases.

20 Cost estimates related to the ETAP are based on EPA ORD experience with conducting the transcriptomic studies (2022 estimates).