# 2 BACKGROUND

## 2.1 CHEMICAL INVENTORIES AND CURRENT LANDSCAPE OF TOXICITY TESTING AND HUMAN HEALTH ASSESSMENTS

The worldwide inventory of commercial and industrial chemicals is substantial and continues to grow. In a survey of 19 countries or regions, more than 350,000 chemicals and mixtures of chemicals were registered in one or more inventories (Wang et al. 2020). In the United States (U.S.), the 2022 Toxic Substances Control Act (TSCA) inventory contained more than 86,000 chemicals, of which approximately 42,000 are considered commercially active.^3^ Both the global and domestic inventories are anticipated to expand in the future. Global chemical production has increased 50-fold since 1950, and is projected to triple again by 2050 compared to 2010 (EEA 2018). Domestically, annual chemical production increased an average of 3% per year between 2012 and 2019 (NASEM 2022). While much of the worldwide and domestic chemical production on a volume basis is attributed to a relatively small number of commodity chemical classes, the diversity in chemical structures on various inventories is due to the rising demand for specialty chemicals across a range of industries. For regulatory agencies such as the U.S. Environmental Protection Agency (EPA), the overall consequence of the historical, current, and future trends in chemical production is a substantial and increasing number of chemicals requiring toxicity testing to evaluate potential for human health risks.

Toxicity testing in experimental laboratory settings is an important component in assessing potential human health impacts of chemicals. Traditional methods for characterizing the toxicity of chemicals typically involve the use of animal models in standard guideline studies. These guideline studies cover a range of exposure durations (e.g., acute, subacute, subchronic, chronic) and health effect domains (e.g., general systemic toxicity, reproductive, developmental, immunotoxicity). Chemical testing requirements vary depending on the intended use and the specific statutes governing those uses. For example, a full battery of toxicology studies is required for a food-use pesticide under 40 CFR Part 158^4^, whereas no specific toxicology studies are required for commercial and industrial chemicals under TSCA. Under the current toxicity testing requirements, a relatively small portion of chemicals in commercial use (15%) have been evaluated with traditional animal-based toxicity tests (Figure 2-1). A smaller percentage of chemicals have toxicity testing data for more specialized endpoints such as developmental (10%), reproductive (2%), and neurotoxicity (1%). The lack of toxicity data poses significant challenges for EPA in evaluating potential human health impacts of the large number of chemicals within its regulatory purview.

Figure 2-1 The percentage of chemicals on the 2022 TSCA active inventory with available information from traditional animal-based toxicity tests. The pie chart represents chemicals on the TSCA active inventory with any repeated dose toxicity study (‘Yes’; Orange). The bar chart on the right provides a breakdown of the repeated dose toxicity tests health outcome domains by endpoint. The total percentage may not add up to 15% since some chemicals may have been tested for more than one type of health outcome. Data were obtained from ToxValDB v9.4.

Human health assessments integrate the results of human epidemiological and experimental animal toxicity tests and other relevant information to identify exposure levels at which no adverse health effect(s) is anticipated over a given duration of exposure (e.g., lifetime). Within the EPA, human health assessments inform a broad range of regulatory decisions such as setting water quality standards, establishing remediation levels at contaminated sites, identifying standards for manufacturing, disposal, and air emissions, and determining safe uses. To develop a human health assessment, significant effort is required to identify and assemble the various sources of experimental animal toxicology and human studies, and to systematically examine the studies for quality and relevance. Once the studies are reviewed and evidence assembled, the candidate critical toxicological effects are identified for dose-response modeling and point of departure (POD)^5^ identification. Based on considerations such as quantitative sensitivity across the candidate PODs, a POD is selected and then divided by a number of uncertainty (or safety) factors that address important experimental, variability, and extrapolation considerations (EPA 2002). The resulting study review, hazard and dose-response assessment, reference value derivation, and assessment conclusions are summarized, undergo requisite review, and are published. Each step in this process is time and resource intensive, such that the development of human health assessments typically takes at least 4 years (Krewski et al. 2020), while more complex assessments can take substantially longer (NASEM 2009). Due to the lack of toxicity testing data for many chemicals in commerce and the time required to develop human health assessments, few chemicals have published reference values. Among chemicals on the TSCA active inventory, only 1.8% have a published human health assessment from EPA or the Agency for Toxic Substances and Disease Registry (ATSDR) (Figure 2-2). None of the individual federal sources have developed human health assessments on more than 1% of chemicals on the TSCA active inventory.

Figure 2-2 The percentage of chemicals on the 2022 TSCA active inventory with human health assessments from representative US federal agencies. The pie chart represents chemicals on the TSCA active inventory with any human health assessment (‘Yes’; Orange). The bar chart on the right provides a breakdown of the human health assessments from different sources including the EPA Integrated Risk Information System (IRIS) database, EPA Provisional Peer Reviewed Toxicity Values (PPRTV), Agency for Toxic Substances and Disease Registry (ATSDR) Minimum Risk Levels (MRL), EPA Office of Water Drinking Water Standards (OW DWS), and Office of Pesticide Program (OPP). The total percentage may not add up to 1.8% since some chemicals may have an assessment from more than one source.

## 2.2 VALUE OF INFORMATION ANALYSIS

To address the gap in availability of human health assessments, the EPA has committed to developing and refining scientifically robust methods for characterizing chemical hazard and exposure with the specific goal of making risk assessments more expedient and economical (Cote et al. 2012; Krewski et al. 2014). Moving the science of human health risk assessment forward will require both the development of novel toxicity testing methods and approaches, as well as associated frameworks to assess their value for informing decision making in a variety of decision contexts. A key aspect of assessing that value involves the decision to take an immediate action with currently available information versus delaying until additional data are collected and analyzed. This choice is often informed by the urgency of the public health need and the costs, in terms of both time and resources, of acquiring additional relevant information that may lead to decisions with less uncertainty. The U.S. National Academies of Sciences, Engineering, and Medicine (NASEM), in its report Science and Decisions: Advancing Risk Assessment, reflected that time is a major and rarely acknowledged factor in risk assessment and that additional studies may reduce uncertainty, but the delay can have significant impact on society and communities who are exposed to a chemical or substance while awaiting the results (NASEM 2009). The NASEM Committee recommended the development and application of Value of Information (VOI) analysis to provide a more objective decision framework to evaluate the potential impact of information on a particular decision or proposed changes in risk assessment activities (NASEM 2009).

VOI analysis is a decision analytic methodology for quantifying the expected gain in reducing uncertainty through the collection of additional data or information (Howard 1966; Raiffa 1968). In general terms, the value of the information is calculated based on the expected reduction in probability of making the wrong decision multiplied by the consequences of being wrong. The result of the calculation is compared with the expected cost of the information. If the expected value obtained is favorable with respect to the costs incurred, then the additional information should be collected. If not, then the value of additional information is not worth the cost and should not be collected. Like traditional sensitivity and uncertainty analysis, VOI analyses capture the influence of uncertain parameters and model structures on model outcomes. However, in VOI, the focus is not necessarily on individual model outputs, but rather the focus is on a specific decision to be made and the potential impacts of collecting additional information (Zabeo et al. 2019). For toxicology, exposure characterization, and human health risk assessment, VOI has been applied or proposed in a variety of decision contexts (Finkel and Evans 1987; Lave and Omenn 1986; Lave et al. 1988; Leontaridou et al. 2016; Taylor et al. 1993; Thompson and Evans 1997; Yokota et al. 2004; Yokota and Thompson 2004).

The EPA Office of Research and Development (ORD) recently developed a VOI framework for comparing human health and economic benefits of toxicity-testing methodologies (Hagiwara et al. 2022). The ORD VOI framework focuses on the value of collecting toxicity testing information based on two types of risk management strategies: the target-risk decision maker (TRDM) whose objective is to control potential health risks whenever it is thought to exceed a specified target risk level (TRL); and the benefit-risk decision maker (BRDM) whose objective is to balance the cost of exposure mitigation and the resulting health benefits. To calculate the human health and economic value of the toxicity testing information, the framework incorporates a series of input parameters relevant to chemical risk assessment that would be considered by risk managers, including chemical exposure, associated adverse health effects, costs of potential exposure mitigation actions, the size of affected populations, and the amount of uncertainty reduced in human health assessments by performing the toxicity tests. The ORD VOI framework builds on previous work in the field by explicitly incorporating the value of additional toxicity testing data while accounting for the cost of delay in decision making that results from the time required for testing. To illustrate its potential application, the publication outlining the VOI framework considered two different hypothetical toxicity tests (a low-cost and short-duration test with greater uncertainty and a high-cost long-duration test with less uncertainty). The results from the comparison considered in the framework paper indicated that the time required to perform the toxicity testing was a strong determinant of the VOI, even when the degree of uncertainty reduction was less than could be achieved with a more time and resource intensive toxicity testing method.

3 US EPA TSCA Inventory: https://www.epa.gov/tsca-inventory

4 EPA Data Requirements for Pesticide Registration: https://www.epa.gov/pesticide-registration/data-requirements-pesticide-registration

5 In human health risk assessment practice, a point-of-departure (POD) represents the dose-response point that marks the beginning of a low-dose extrapolation. This point can be the lower bound on dose for an estimated incidence or a change in response level from a dose-response model (e.g., Benchmark Dose; BMD), or a No Observed Adverse Effect Level (NOAEL) or Lowest Observed Adverse Effect Level (LOAEL) for an observed effect.