# 8 SUPPLEMENTAL MATERIAL

The supplemental material includes VOI sensitivity results described via eight tables. Supplemental material can be accessed at https://doi.org/10.23645/epacomptox.26093572.v1 as an Excel spreadsheet with individual tables delimited via tabs. The ‘Read Me’ tab in the spreadsheet includes a copy of the table below.

Table / Tab | Content
S 6.2.1 BRDM | Results of VOI sensitivity analysis evaluating the effect of quality of exposure information for BRDM
S 6.2.1 TRDM | Results of VOI sensitivity analysis evaluating the effect of quality of exposure information for TRDM
S 6.2.2 | Results of VOI sensitivity analysis evaluating the effect of adverse health outcome and cost of control for BRDM and TRDM
S 6.2.3 A | Results of VOI sensitivity analysis evaluating the effect of assessment duration for BRDM and TRDM
S 6.2.3 B | Results of VOI sensitivity analysis evaluating the effect of time horizon for BRDM and TRDM
S 6.2.3 C | Calculation of total benefits realized within a pre-specified time horizon
S 6.2.5 BRDM | BRDM Results of VOI sensitivity analysis evaluating the effect of affected population size for BRDM
S 6.2.5 TRDM | Results of VOI sensitivity analysis evaluating the effect of affected population size for TRDM