# ABBREVIATIONS

AHC: Annualized Health Cost
ACC: Annualized Control Cost
ASD: Autism Spectrum Disorders
ATSDR: Agency for Toxic Substances and Disease Registry
BMD: Benchmark Dose
BMDL: Benchmark Dose Lower Confidence Bound
BOSC: Board of Scientific Counselors
BRDM: Benefit-Risk Decision Maker
CCED: Chemical Characterization and Exposure Division
CCTE: Center for Computational Toxicology and Exposure
COD: Cost of Delay
COT: Cost of Testing
CPHEA: Center for Public Health and Environmental Assessment
DAF: Dosimetric Adjustment Factor
ECHA: European Chemicals Agency
ED_50_: Median Effective Dose
ENBS: Expected Net Benefit of Sampling
EPA: U.S. Environmental Protection Agency
ETAP: EPA Transcriptomic Assessment Product
ETHC: Expected Total Health Cost
ETSC: Expected Total Social Cost
EV|CI: Expected Value Given Current Information
EVDSI: Expected Value of Delayed Sample Information
EVIPPI: Expected Value of Immediate Partial Perfect Information
EVISI: Expected Value of Immediate Sample Information
GO: Gene Ontology
GM: Geometric Mean
GSD: Geometric Standard Deviation
HD_M_^I^: Human Dose at Magnitude (M) and Incidence (I)
HED: Human Equivalent Dose
ID: Intellectual Disability
IPCS: International Programme on Chemical Safety
IRIS: Integrated Risk Information System
K: Thousand(s)
LOAEL: Lowest Observed Adverse Effect Level
M: Million(s)
MRL: Minimum Risk Level
NASEM: U.S. National Academies of Sciences, Engineering, and Medicine
NCEE: U.S. EPA National Center for Environmental Economics
NOAEL: No Observed Adverse Effect Level
NTP: National Toxicology Program
OM: Orders of Magnitude
OPP: Office of Pesticide Programs
ORD: Office of Research and Development
ORE: Optimal Reduction in Exposure
OW DWS: Office of Water Drinking Water Standards
PM: Particulate Matter
POD: Point of Departure
PPI: Partial Perfect Information
PPRTV: EPA Provisional Peer Reviewed Toxicity Value
REACH: European Regulation on Registration, Evaluation, Authorisation and Restriction of Chemicals
RfD: Reference Dose
RMSD: Root Mean Squared Difference
RNA: Ribonucleic Acid
RNA-seq: RNA Sequencing
ROI: Return on Investment
RSL: Regional Screening Level (Superfund)
SAB: U.S. EPA Science Advisory Board
SEM: Systematic Evidence Map
SHEDS-HT: U.S. EPA's High-Throughput Stochastic Human Exposure and Dose Simulation Model
TCC: Total Control Cost
TD: Toxicodynamic
TH: Time Horizon
THC: Total Health Cost
THHA: Traditional Human Health Assessment
TK: Toxicokinetic
ToxValDB: U.S. EPA Chemicals Dashboard ToxVal database
TRDM: Target-Risk Decision Maker
TRL: Target Risk Level
TSC: Total Social Cost
TSCA: Toxic Substances Control Act
TRV: Transcriptomic Reference Value
UF: Uncertainty Factor
VOC: Volatile Organic Compounds
VOI: Value of Information
VSL: Value of a Statistical Life