# Reviewers

This document has been provided for review to EPA scientists, and peer reviewed by independent scientists external to EPA (listed below). A summary of comments and EPA’s response to comments received from the independent external peer reviewers is provided through EPA’s Science Inventory database of publicly released research products which is available by clicking here (https://cfpub.epa.gov/si/si_public_pra_view.cfm?dirEntryID=349776&Lab=CCTE).

- Dr. Tara S. Barton-Maclaren, Health Canada
- Dr. Weihsueh A. Chiu, Texas A&M University
- Dr. Helen M. Goeden, Minnesota Department of Health
- Dr. Kerry W. Nugent, Australian Industrial Chemicals Introduction Scheme (formerly NICNAS)
- Dr. Edward J. Perkins, Department of Defense