# Acknowledgements

This report was developed by the United States Environmental Protection Agency (U.S. EPA), Office of Chemical Safety and Pollution Prevention (OCSPP) and the Office of Research and Development (ORD).