# 7 Conclusion

The EPA has developed the PICS approach to integrate information from a variety of sources to better understand the landscape of publicly available information for these chemical substances. The automated approach provides a systematic and reproducible process for integrating available information and identifying potential information gaps. Over time, the PICS approach will increase efficiency and workload management by focusing expert review on substances that may have a greater potential for selection as high- or low priority potential candidates. The domain-specific workflows embedded in the approach can be adapted to scientific advances or the availability of new information to create a flexible and sustainable process. The proof-of-concept study suggests that the PICS approach can help inform chemical prioritization, identify possible data gaps which can inform data needs, and provide other information related to the EPA’s TSCA program. The PICS approach is designed in discrete domains and utilizes well-documented data sources which allows flexibility for future adaptation and customization as needed to meet program requirements or needs that might be different to those of the TSCA. In addition, the approach may also be useful in identifying common data gaps across large groups of chemicals, which could facilitate research efficiencies.