# 3 Background

## 3.1 Development and Implementation of New Approach Methods Under TSCA

Section 4 (h) of the Toxic Substances Control Act (TSCA), as amended by the Frank R. Lautenberg Chemical Safety for the 21st Century Act (P.L. 114-182), requires EPA to develop a Strategic Plan to promote the development and implementation of alternative test methods and strategies to reduce, refine or replace vertebrate animal testing and provide information of equivalent or better scientific quality and relevance for assessing risks of injury to health or the environment of chemical substances or mixtures. EPA’s Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program^8^ was released on June 22, 2018 and outlines the EPA’s plan to reduce the use of vertebrates for chemical substances regulated under TSCA. As part of this Strategic Plan, EPA describes incremental steps for the development and integration of NAMs that are appropriate and fit-for-purpose for making TSCA-related decisions (e.g., identifying candidates for prioritization, prioritization, risk evaluations for new and existing chemical substances and other risk-based decisions). This multi-year strategic plan includes criteria for determination of what would be considered NAMs by the EPA and how they may be applied for evaluation of human health hazard, ecological hazard and exposure. In addition to this, EPA has developed a NAMs workplan ^9^ for reducing use of animals in chemical testing in order to prioritize Agency efforts and resources toward activities that aim to reduce the use of animal testing while continuing to protect human health and the environment. This workplan expands EPA’s discussion of the development and use of NAMs for support of regulatory decision-making beyond TSCA and focuses on mechanisms for building confidence in the implementation of NAMs.

## 3.2 Evaluating Existing Chemicals Under TSCA

Under Section 6(b) of TSCA, EPA is required to both prioritize and evaluate the risks of existing chemical substances. The law contains specific timetables, minimum chemical substance numbers, and general requirements for both prioritization and risk evaluation. Prioritization^10^ is a 9- to 12-month public process in which chemical substances are designated as either high- or low priority for risk evaluation. A high priority chemical substance is one “that the Administrator concludes, without consideration of costs or other non-risk factors, may present an unreasonable risk of injury to health or the environment because of a potential hazard and a potential route of exposure under the conditions of use, including an unreasonable risk to potentially exposed or susceptible subpopulations identified as relevant by the Administrator.” A low priority chemical substance is one that “the Administrator concludes, based on information sufficient to establish, without consideration of costs or other non-risk factors, that such chemical substance does not meet the [High priority] standard.” A designation of a chemical substance as low priority indicates that a risk evaluation is not warranted at that time.

TSCA requires that high priority chemical substances undergo risk evaluation to determine whether a chemical substance presents an unreasonable risk of injury to health or the environment, without consideration of costs or other non-risk factors, including an unreasonable risk to a potentially exposed or susceptible subpopulation^11^ identified as relevant to the risk evaluation by the Administrator, under the conditions of use^12^. The risk evaluation must take no longer than three years with a possible six-month extension. If unreasonable risk is identified, EPA has two years with a possible extension of two additional years to finalize regulations so the chemical substance no longer presents such a risk.

On March 20, 2019, the EPA initiated the prioritization process for the first set of 20 high-and 20 low priority candidate chemical substances. The initiation of the prioritization process is followed by a 90-day public comment period for submitting relevant information. Upon completion of the public comment period, the EPA performs a screening review of the candidate chemical substances based on hazard and exposure potential, persistence and bioaccumulation, potentially exposed or susceptible subpopulations, storage near significant sources of drinking water, the conditions of use, and the volume of the chemical substance manufactured or processed. Based on the outcome of the screening review, the EPA will propose to designate a chemical substance as either a high priority or low priority chemical substance and release the information, analysis, and basis used to make the designation. The proposed designation will be followed by a second 90-day comment period prior to finalizing the designation.

## 3.3 Public Engagement

On December 11, 2017, EPA held a public meeting to gain input regarding identification of potential candidate chemical substances for prioritization. In preparation for this meeting, EPA published a discussion document including possible approaches to inform the dialogue at the meeting^13^. A Response to Comment document has been developed to address the comments^14^. EPA received 43 relevant comments in the docket associated with the public meeting^15^. There was consensus in the comments that EPA should proceed in a transparent manner with opportunities for public participation. However, there was no consensus around one or more of the proposed approaches the Agency presented. The most consistent support focused on use of the 2014 Update to the TSCA Work Plan^16^ as the starting point for identifying high priority candidates. For low priority chemical substances, there was some support for using the chemical substances on the Safer Chemical Ingredients List (SCIL)^17^, which was developed by EPA’s Safer Choice Program, as a starting point. There was general support for the integration of NAMs for filling information gaps during the process to identify potential candidate chemical substances for prioritization; however, there was some concern regarding the readiness of these approaches for decision-making on prioritization for risk evaluation. There were opposing views regarding filling information gaps and EPA’s authority to request submission of information, the use of voluntary submissions, when to request information, the quality of information, and how to use information from other jurisdictions (e.g., the European Union’s Registration, Evaluation, Authorisation, and Restriction of Chemicals (REACH)).

On September 27, 2018, EPA released A Working Approach for Identifying Potential Candidate Chemicals for Prioritization^18^ (to be called Working Approach for Potential Candidates throughout this document) that described both short- and long-term strategies for selecting candidate chemical substances for prioritization under TSCA. The long-term strategy in the Working Approach for Potential Candidates was adapted from the TSCA 2012 Work Plan process^19^, but incorporated scientific advances in relevant fields, integration of NAMs, and modern information management technologies to integrate the large volume of information in an efficient, automatable and reproducible manner. The strategies presented in the Working Approach for Potential Candidates reflected public input received at the December 2017 meeting^20^ and through the public docket for that meeting^21^. EPA accepted a second round of public comments on the proposed longer-term strategy. EPA received 26 unique comments in the docket^22^. Commenters also noted that data gaps do not necessarily equate to data needs, and that EPA should not prioritize solely based on information availability. Commenters included recommendations on specific topics, including susceptible and sensitive populations and increasing the use of exposure data to make this approach more risk-based. The comments also highlighted the need to clarify the purpose of the long-term strategy as a means for increasing efficiency of the expert review required for the selection of candidates for prioritization and not as a replacement for the formal prioritization and risk evaluation steps in the process. Finally, there appeared to be misconceptions about the difference between the bins outlined in the strategy and the chemical substance categories the Agency regularly uses in the TSCA New Chemicals Program to group chemical substances expected to show the same hazard characteristics. The present document and the PICS approach are intended to address these comments.

8 Alternative Test Methods and Strategies to Reduce Vertebrate Animal Testing in TSCA (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/alternative-test-methods-and-strategies-reduce).

9 More information can be found at https://www.epa.gov/chemical-research/epa-new-approach-methods-work-plan-reducing-use-animals-chemical-testing

10 Final Rule, “Procedures for Prioritization of Chemicals for Risk Evaluation Under the Toxic Substances Control Act,” available at https://www.regulations.gov/document?D=EPA-HQ-OPPT-2016-0636-0074.

11 “Potentially exposed or susceptible subpopulation,” as defined in TSCA Section 3(12), means a group of individuals within the general population identified by the Administrator who, due to either greater susceptibility or greater exposure, may be at greater risk than the general population of adverse health effects from exposure to a chemical substance or mixture, such as infants, children, pregnant women, workers or the elderly (15 U.S.C. 2602).

12 “Conditions of use” under TSCA means “the circumstances, as determined by the Administrator, under which a chemical substance is intended, known, or reasonably foreseen to be manufactured, processed, distributed in commerce, used or disposed of” (15 U.S.C. 2602). For purposes of prioritization, the Administrator may determine that certain uses fall outside the definition of “conditions of use”.

13 Meeting materials for the December 11, 2017 Possible Approaches for Identifying Potential Candidates for Prioritization Public meeting can be found here: https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/possible-approaches-identifying-potential-candidates .

14 https://www.epa.gov/sites/production/files/2018-09/documents/publiccommentssummary_dec11_preprioritization_927.pdf

15 The public comments received following the December 11, 2017 public meeting are available at www.regulations.gov in docket [underlined: EPA-HQ-OPPT-2017–0586].

16 https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/tsca-work-plan-chemical-assessments-2014-update

17 This list can be found at https://comptox.epa.gov/dashboard/chemical_lists/SCILFULL

18 https://www.epa.gov/sites/production/files/2018-09/documents/preprioritization_white_paper_9272018.pdf

19 https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/tsca-work-plan-methods-document

20 https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/meetings-and-webinars-amended-toxic-substances-control#12/11

21 Further information can be found at docket EPA-HQ-OPPT-2017–0587.

22 Further information can be found at docket EPA-HQ-OPPT-2018–0659.