# 1 Executive Summary

Regulatory agencies worldwide are looking to efficiently integrate information on chemical substances^1^ in order to inform priorities for decisions and data requests. This document updates the US Environmental Protection Agency’s (EPA) long-term strategy described in the Working Approach for Identifying Potential Candidate Chemicals for Prioritization^2^ and presents the Public Information Curation and Synthesis (PICS) approach that integrates publicly-available hazard, exposure, persistence, and bioaccumulation information for chemical substances. The purpose of the PICS approach is to synthesize information from traditional and new approach methods (NAMs)^3^ to understand the overall degree of potential concern as well as the relative coverage of potentially relevant human health and ecological toxicity and exposure information that could inform level of effort and resources that may be needed to evaluate that specific chemical substance. The PICS approach is based on two dimensions. The first dimension, Scientific Domain Metric (SDM), encompasses the synthesis of the traditional and NAM data to understand the overall degree of potential concern related to human health and the environment. The second dimension, Information Availability Metric (IAM), reflects the relative coverage of potentially relevant human health and ecological toxicity and exposure information that could inform level of effort and resources that may be needed to evaluate that specific chemical substance. The PICS approach is not designed to replace the prioritization process described in TSCA but aims to increase efficiency and focus expert review on chemical substances that may have a greater potential for designation as a high- or low priority candidate. A proof-of-concept case study was performed by applying the PICS approach to a subset of the TSCA active inventory. The results demonstrate that the approach discriminated between high- and low priority candidate chemical substances and identified potential information gaps. The PICS approach may be applied to large numbers of chemical substances and is an important tool for efficiently integrating and synthesizing large amounts of publicly available information, and aspects of the approach could be adapted and applied to other prioritization decision contexts.

1 Unless otherwise indicated, any references to “chemical” or “chemical substance” throughout this document means a “chemical substance” as defined in TSCA Section 3(2).

2 https://www.epa.gov/sites/production/files/2018-09/documents/preprioritization_white_paper_9272018.pdf

3 https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/alternative-test-methods-and-strategies-reduce The term NAMs was recently introduced to cover any in vitro, in silico, or in chemico technique used to provide data or information for regulatory decision making.