# Appendix G Information Availability Metric Calculation

Figure G-1 Flow chart explaining the Information Availability Metric (IAM) calculation used in the PICS approach.