# Appendix F Comparison of Individual Scientific Domain Metrics for the POC238 and Non-confidential TSCA Active Inventory

Below are the results for the full PICS approach and the individual metrics for the POC238 subset as compared to the non-confidential TSCA active inventory. As expected, these comparisons show that the POC238 subset is more data-rich than the full non-confidential TSCA active inventory. This level of detail could allow the decision-maker to examine if any specific endpoint is potentially of more concern than any other and to explore potential data gaps for the chemical group of interest.

Figure F-1 Plot of the Information Availability vs. Scientific Domain Metrics for the POC238 set of chemical substances (left) and non-confidential TSCA active inventory (right). Each dot represents one chemical substance, with the size of the dot representing the number of domains with data for the specific chemical. The red dots represent the first ten TSCA Work Plan chemical substances selected for risk evaluation in 2016 (TSCA 10). The green dots represent the TSCA Work Plan chemical substances from the 2014 update (TSCA 90). The red triangles represent the high priority chemical substances and the yellow triangles represent the low priority chemical substances released in March 2019. The blue dots represent the high molecular weight compounds and exempt polymers and the small black dots represent the remaining compounds in the inventory. Positions of points are staggered for ease of visualization.

Figure F-2 Distributions of the scaled SDM and IAM for the POC238 subset and non-confidential TSCA active inventory. The x-axis displays the scaled value and the y-axis shows the frequency of that value in the subset.

Figure F-3 Distributions of the scaled SDM for the individual domains for the POC238 subset. The x-axis displays the scaled value and the y-axis shows the frequency of that value in the subset.