# Appendix E Public Information Curation and Synthesis (PICS) Output for Proof-of-Concept (POC) Subset of the Non-confidential TSCA Active Inventory

Attached is the output results for the proof-of-concept subset used to inform the Public Information Curation and Synthesis (PICS) Approach. This data can also be viewed at https://ccte-tscapoc.epa.gov. Results were determined as described in the text and displayed visually in Figure 14 of the report.

Order | Column | Description
1 | DTXSID | DSSTox generic substance ID
2 | CASRN | Chemical Abstracts Registry Number
3 | Name | Chemical Name
4 | TSCA Active | Is the chemical in the TSCA Active Inventory?
5 | TSCA 90 | Is the chemical in the 2014 update to the TSCA Workplan?
6 | TSCA POC | Is the chemical in the TSCA POC (this list)?
7 | TSCA 10 | Is the chemical in the 2016 Work Plan Chemicals?
8 | SCIL | Is the chemical in the EPA Safer Chemicals Ingredients List (SCIL)?
9 | SCIL Green Circle | Is the chemical in the SCIL Green Circle List?
10 | SCIL Half Green Circle | Is the chemical in the SCIL Half Green Circle List?
11 | SCIL Yellow Triangle | Is the chemical in the SCIL Yellow Triangle List?
12 | SCOGS GRAS | Is the chemical in the FDA Generally Regarded as Safe (GRAS) List?
13 | Intentional Food Ingredient | Is the chemical in the FDA Substances Added to Food Inventory?
14 | IRIS | Is the chemical in the EPA IRIS Inventory?
15 | PPRTV | Is the chemical in the EPA PPRTV Inventory?
16 | SIDS | Is the chemical in the OECD Screening Information Data Set List?
17 | TSCA Low Priority | Is the chemical in the High Priority TSCA list?
18 | TSCA High Priority | Is the chemical in the Low Priority TSCA list?
19 | Scientific Domain Metric | The value of the scientific domain metric (range from 0–100)
20 | Information Availability Metric | The value of the information availability metric (range from 0–100)
21 | Public Risk Assessment Noncancer | If there is a public non-cancer risk assessment, lists whether there is an RfD and/or RfC available
22 | Public Risk Assessment Cancer | If there is a public cancer risk assessment, lists whether there is an slope factor and/or unit risk available
23 | IG Flag (human hazard) | Information gathering flags for human hazard
24 | IG Flag (ecological hazard) | Information gathering flags for ecological hazard
25 | IG Flag (genotoxicity) | Information gathering flags for genotoxicity
26 | IG Flag (cancer) | Information gathering flags for cancer
27 | IG Flag (childrens exposure) | Information gathering flags for children’s exposure
28 | IG Flag (persistence / bioaccumulation) | Information gathering flags for persistence / bioaccumulation
29 | IG Flag (sensitization / irritation) | Information gathering flags for sensitization / irritation
30 | Score human hazard to exposure ratio | Score for human hazard to exposure ratio (range of 0–4)
31 | Score ecological hazard | Score for ecological hazard (range of 0–4)
32 | Score cancer | Score for cancer (range of 0–4)
33 | Score genotoxicity | Score for genotoxicity (range of 0–4)
34 | Score children | Score for children’s exposure (range of 0–4)
35 | Score persistence / bioaccumulation | Score for persistence / bioaccumulation (range of 0–4)
36 | Score sensitization irritation | Score for sensitization / irritation (range of 0–4)
37 | Human hazrd to exposure ratio (repeat dose) | Minimum repeat-dose mammalian POD / exposure estimate
38 | POD mammalian in vivo oral repeat dose (mg/kg/day) | Minimum repeat-dose mammalian POD
39 | Estimated human exposure (mg/kg/day) | Human exposure estimate from the SEEM3 model
40 | Minimum aquatic ecological POD (mg/L) | Minimum aquatic ecological POD (experimental repeat dose or acute or predicted)
41 | Ecological aquatic POD in vivo acute (mg/L) | Minimum aquatic ecological POD in vivo, acute
42 | Ecological aquatic POD in vivo repeat dose (mg/L) | Minimum aquatic ecological POD in vivo, repeat dose
43 | Data available (mammalian acute) | Is there an experimental mammalian POD for an acute toxicity study?
44 | Data available (mammalian subchronic) | Is there an experimental mammalian POD for a subchronic toxicity study?
45 | Data available (mammalian chronic) | Is there an experimental mammalian POD for a chronic toxicity study?
46 | Data available (mammalian repeat dose) | Is there an experimental mammalian POD for a repeat dose toxicity study?
47 | Data available (mammalian developmental) | Is there an experimental mammalian POD for a developmental toxicity study?
48 | Data available (mammalian reproductive) | Is there an experimental mammalian POD for a reproductive toxicity study?
49 | Data available (mammalian neurotoxicity) | Is there an experimental mammalian POD for a neurotoxicity study?
50 | Data available (ecological acute plant) | Is there an experimental ecological POD for an acute plant study?
51 | Data available (ecological acute invertebrate) | Is there an experimental ecological POD for an acute invertebrate study?
52 | Data available (ecological acute vertebrate) | Is there an experimental ecological POD for an acute vertebrate study?
53 | Data available (ecological repeat dose plant) | Is there an experimental ecological POD for a repeat dose plant study?
54 | Data available (ecological repeat dose invertebrate) | Is there an experimental ecological POD for a repeat dose invertebrate study?
55 | Data available (ecological repeat dose vertebrate) | Is there an experimental ecological POD for a repeat dose vertebrate study?