# Appendix D Definition of Exposure Pathways for Calculating the Susceptible Population Domain Metric

Exposure Source | Definition | Data Source | Primary Contributors to Increased Children’s Exposure versus the General Population | Exposure Differential Metric
Consumer Sources-Children’s Products | Known occurrence (via reporting or measurement) in consumer products used more commonly (or exclusively) by children (e.g., arts and crafts formulations, baby preparations, car seats and other gear, toys, and marketed to children such as children’s sunscreens). Known occurrence in products to which infants or children have closer contact than adults due to behavior (i.e., carpet, flooring) | CPDat: reported presence of chemical in a product used primarily by children; CPCat: chemicals directly reported or measured in children’s products; chemicals reported or detected in flooring (e.g., carpet, carpet padding); 2016 CDR Consumer/Commercial Use Information: flag for use in children’s products | Increased prevalence of use by children versus adults; closer proximity of source to children compared to adults | 4
Breast Milk or Formula | Chemical detected in breast milk or formula | Lehmann GM, LaKind JS, Davis MH, Hines EP, Marchitti SA, Alcala C, and Lorber C. (2018) Environmental chemicals in breast milk and formula: Exposure and risk assessment implications. Environ Health Perspect, 126: 96001 | Source unique to children | 4
Dust | Measured in residential house dust in at least two studies in published meta-analysis. | Mitro SD, Dodson RE, Singla V, Adamkiewicz G, Elmi AF, Tilly MK, and Zota AR. (2016). Consumer product chemicals in indoor dust: A quantitative meta-analysis of U.S. studies. Environ Sci Technol, 50: 13611–11. | Increased contact by children; increased hand-to-mouth behaviors (and thus chemical ingestion); closer proximity of source to children (e.g., within children’s breathing zone) | 3
Consumer Sources – Flooring and Related Products | Known occurrence (via reporting or measurement) in flooring or floor coverings, or in products used on these items (such as cleaners) | CPDat: reported presence of chemical in a flooring related product, CPCat: presence in consumer product categories associated with flooring or related products; 2016 CDR Consumer/Commercial Use Information: reported in product categories associated with flooring | Increased contact by children; Increased hand-to-mouth behaviors (and thus chemical ingestion); closer proximity of source to children (e.g., within children’s breathing zone) | 3
Consumer Sources – Other Products (General Population) | Known occurrence (via reporting or measurement) in consumer products not captured elsewhere that may be either used by children or transferred to children by adults | CPDat: reported presence in consumer products; CPCat: presence in general consumer product categories; 2016 CDR Consumer/Commercial Use Information: reported as having “Consumer” use or “Both” (consumer and commercial) | Increased hand-to-mouth behaviors (and thus chemical ingestion); increased inhalation rates of children versus adults | 2
Dietary Sources | Chemicals in food packaging (indirect food additives), direct food additives, agricultural chemicals, chemicals measured in drinking water | CPCat: presence in related categories; 2016 CDR Consumer/Commercial Use Information: presence in food-related product categories | Increased food consumption per unit body weight by children | 1
Far-field Sources | Industrial pollutants (which may be released the environment and result in ultimate exposures via contact with contaminated media) | CPCat: presence in industrial use categories; 2016 CDR Industrial Process and Use Information: chemical was reported | Increased hand-to-mouth behaviors (and thus chemical ingestion); increased inhalation rates of children versus adults | 1