# Appendix C Quality Assurance Recommendations to Efficiently Review Datasets to Support Candidate Chemical Identification for TSCA

## Overview

This appendix describes the approaches that ORD implemented to ensure a high standard of review of compiled publicly available information from Type 1 data sources on the proof-of-concept 238 chemical substances (POC238). The data curation effort reviewed chemical, toxicological, and exposure data to confirm accuracy. Specific details about the review processes for each data domain are described below.

The QC review approaches were developed in a “learn-by-doing” pilot study using the POC238. The pilot study developed methods for data aggregation, curation, and evaluation, as well as recommendations to efficiently review large Type 1 datasets. The TSCA data curation team consisted of scientists from ORD organized into workgroups based on expertise and given data for review.

### Procedures for QC review

Chemical data were sorted into six data domains: human hazard, exposure, genotoxicity, ecological hazard, skin sensitization and skin/eye irritation, and bioaccumulation. Data on the chemicals were collected from Type 1 data sources [as defined in A Working Approach for Identifying Potential Candidate Chemicals for Prioritization^118^; see Appendix B for Data Source list]. Type 1 data sources are publicly available and readily searchable, enabling data extraction in a structured form. To review these data, workgroups were organized according to scientific expertise. Each workgroup established a process for reviewing their data domain and these processes are summarized below.

No study quality considerations were evaluated during QC review. Reviewers did not perform a critical analysis of experimental design, statistical analyses, or data interpretation. Rather, reviewers compared the collected Type 1 data to primary and secondary sources. A primary source was defined as the study, report, or manufacturer report with health safety data. A secondary source was defined as a database or source that provided data aggregated from multiple primary sources.

Reviewers flagged data that could not be confirmed to the primary source, even if the aggregated data matched the secondary source. However, certain secondary sources, such as the ECOTOX Knowledgebase^119^, the Integrated Risk Information System (IRIS)^120^, or exposure data^121^ have existing QC processes or peer review processes. For these select databases, confirmation to secondary source was sufficient to pass QC review. Reviewers recorded reasons for QC flags and developed QC metrics for data errors. “QC flag” measured the percentage of data without confirmation to the primary source. “Error rate” determined how often a secondary source incorrectly reported a value from a primary source.

The workgroups collected metrics on the data sources. The QC flag metric reported the percentage of data points that could not be confirmed to a primary source, for example, in instances where the primary source was not available. QC flag metric was calculated by dividing the number of data points that were flagged by the total number of data points reviewed. Error rate measured how often a secondary database did not match the primary source, that is when both the primary source and secondary source are available, but the values do not match. Error rate was calculated by dividing the number of data points that did not match the primary source by the number of data points that have both a primary and secondary source.

### Human Hazard Domain Workgroup Review Approach

Human hazard data consisted of in vivo data aggregated from publicly available databases. Data were provided in a spreadsheet for the workgroup to review. A single scientist was assigned to review an individual data source. The human hazard workgroup QC review focused on a subset of the aggregated Type 1 data: chemical identifier, route of exposure, study duration, and point-of-departure (POD) data.

Each reviewer compared the chemical identifier, route of exposure, study duration, and POD data to the secondary source - i.e., the Type 1 source from which data were extracted. In addition, each reviewer attempted to link data points to a primary source – i.e., the original reference. If data could not be confirmed to a primary reference, the data was flagged. However, the workgroup recognized that certain secondary sources, such as IRIS^3^, had existing QC processes. For these databases, the secondary source was sufficient to pass QC review.

Study quality considerations were not evaluated during QC review. Reviewers did not review experimental design, statistical analyses, or data interpretation. Rather QC review was limited to comparing the data with primary and secondary sources. The QC review scope was limited for three reasons. First, the study quality would be evaluated during the expert review for candidate selection. However, if a reviewer noted a potential study quality issue, the issue could be recorded for consideration during the subsequent expert review. Secondly, systematic data quality review requires a minimum of two reviewers for each data point. The human hazard workgroup did not have sufficient personnel to have two reviewers per data point within the accelerated timeline of the pilot study. Lastly, determining a POD is often a fit-for-purpose process that may differ between academic, industrial, and regulatory groups. Harmonizing POD selection across studies was beyond the scope of the human hazard workgroup.

### Exposure Domain Workgroup Review Approach

Two datasets were reviewed by the exposure workgroup: exposure model data (including model parameters and outputs) and selected parameters related to susceptible population exposure. Exposure model data estimated potential human exposures via chemical use parameters from publicly available data sources (Wambaugh et al., 2014^122^, Ring et al., 2018^123^). Susceptible population data was limited to potential exposure in children. Susceptible population data consisted of chemical occurrence in the following media: consumer products with which children either directly (children’s products) or indirectly (other household or personal care products) come into contact, flooring product, house dust, breast milk, foods or food-contact materials, or far-field sources. Chemical occurrence data of compounds in house dust^124^ or breast milk^125^ were collected from two primary references. Occurrence data for the remainder of the media were collected from three different secondary data sources: Chemical Data Reporting (CDR)^126^, Chemical and Products Database (CPDat)^127^, and Chemical Product Categories Database (CPCat)^128^. These secondary sources aggregate government and/or manufacturer reported information on chemical presence in various types of consumer products or industrial processes. The exposure data and susceptible life stage data were provided in separate spreadsheets for the workgroup to review. All data were reviewed by at least two workgroup members.

For the exposure model data, the workgroup focused on a subset of chemical use parameters (pesticide active, pesticide inert, production volume) and estimated exposure outputs from the exposure model median. These values were checked for accuracy against the Wambaugh et al. (2014)^6^ and Ring et al. (2018)^7^ references. The workgroup did not do a QC review of all model inputs. Rather, the workgroup focused their review on the 3 of the 5 most predictive heuristics in Wambaugh et al. 2014^6^. The heuristics that were not reviewed were the industrial and/or consumer use of a chemical. The workgroup did not re-run the exposure models to confirm outputs, but instead focused on accurate transposition from the source material.

Susceptible population occurrence data were confirmed by reviewing either the primary sources for house dust^8^ or breast milk^9^ occurrence or the primary sources cited in the secondary sources (i.e., reported information of chemicals contained in consumer products or used in industrial processes in primary references found in secondary sources). When primary sources were derived from secondary sources, the workgroup reviewed chemicals reported in consumer products related to child use, flooring, food or food-contact material, or far-field exposure sources until a primary source was found that met QC requirements. OCSPP uses presence/absence in children’s products is used as an indicator for potential susceptible population exposure during candidate identification. As this metric is binary (i.e., yes/no) rather than weighted (i.e., occurrence in 10 products versus present only in 1 product), the workgroup focused QC review on (a) ease of record access and (b) confirming occurrence in each medium related to susceptible population exposure. House dust and breast milk were confirmed by checking to respective primary sources. However, for all other media, CDR^10^ records were most readily accessible and reviewable in an automated fashion. In addition, CDR^10^ records are manufacturer reported under TSCA, so these records will likely be relevant for candidate chemical identification. For these reasons, CDR^10^ records were reviewed first, and if CDR^10^ records passed QC review, then available CPDat^11^ or CPCat^12^ records were not reviewed. CPDat^11^ records were reviewed if no CDR^10^ data was available or if CDR^9^ records did not pass QC, as CPDat^11^ records link a chemical directly to manufacturer-reported information of compounds in a consumer product. Finally, if neither CDR^10^ nor CPDat^11^ records were available or did not pass QC review, CPCat^12^ data records were reviewed.

As most data for this domain consisted of manufacturer-reported data, no study quality considerations were evaluated during the QC review. The reviewers did not analyze model design, statistical analyses, or data interpretation. Rather the workgroup focused spreadsheet data accuracy relative to primary and secondary sources.

### Genotoxicity Domain Workgroup Review Approach

Genotoxicity data was aggregated from publicly available databases and provided in a spreadsheet for the workgroup to review. A single reviewer was assigned to group of chemicals and asked to review the genotoxicity data for those chemicals. The genotoxicity workgroup focused their QC review on a subset of the aggregated Type 1 data: mutagenicity data and clastogenicity data. The workgroup evaluated data in the standard bacterial mutation assays (the Salmonella and E. coli WP2 strains), as well as three main assays for chromosomal mutation (in vitro chromosome aberration assay, mouse bone-marrow micronucleus assay, and the mouse lymphoma Tk+/- assay). These data were selected based on a comparison of the predictivity of combination of genotoxicity assays to the Salmonella (Ames) mutagenicity assay alone^129^. Using a database of >10,000 compounds, genotoxicity data from two bacterial strains (TA98 and TA100 of Salmonella) identified 93% of the mutagens. When chromosomal mutation assay data were included, 99% of the mutagens were identified. These findings suggest that bacterial and chromosomal mutation data are sufficient for evaluating genotoxicity potential. Each reviewer confirmed selected data back to the secondary source - i.e., the database from which spreadsheet data were extracted. In addition, each reviewer tried to confirm data back to the primary source – i.e., the original reference cited in the secondary source. If data could not be confirmed to a primary reference, the data was flagged.

The genotoxicity workgroup categorized chemicals as “genotoxic,” “non-genotoxic,” or “inconclusive” based on preliminary review of available genotoxicity data. This categorization was not intended to represent a final determination on the genotoxicity of these chemicals. For example, chemical substances with at least one positive genotoxic assay were categorized as genotoxic, with the understanding that further evaluation of study quality and design may lead to a different determination.

### Bioaccumulation Subdomain Workgroup Review Approach

Bioaccumulation data were aggregated from public databases and provided in a spreadsheet for review. All data were reviewed by the workgroup members. The QC review focused on a subset of the bioaccumulation chemical data: bioconcentration factor (BCF) and bioaccumulation factor (BAF).

Chemical data consisted of two categories: experimental data and modeled data. Although more limited, experimental data were given priority. Reviewers attempted to trace experimental data back to a primary source – i.e., the original reference with measured values. If the reviewers could not confirm the data to a primary source, the data was flagged. The workgroup was only able to confirm a small percentage of the data to a secondary source (i.e., the database from which spreadsheet data were extracted) because secondary source no longer existed or contained proprietary data. The QC review pilot study was limited to publicly available data.

For the predicted BCF and BAF values, the workgroup only reviewed publicly available models. Models were re-run and compared with the spreadsheet for accuracy. Where the models produced different values, the values were actively corrected. The workgroup did not QC review the model inputs. For some data, underlying model inputs and predicted values had published QC review processes. Other model outputs did not provide information on model inputs or QC review. The workgroup flagged models that did not have a publicly accessible QC process as a decision point for further consideration.

### Ecological Hazard Domain Workgroup Review Approach

Ecological hazard data consisted of data extracted from two Type 1 sources – the US EPA ECOTOX Knowledgebase^2^ and the European Chemicals Agency (ECHA) database^130^. These data were provided in a spreadsheet for the workgroup to review. A single reviewer was assigned to a group of chemicals and asked to review the ecological hazard data for those chemicals. The ecotoxicology workgroup reviewed a large amount of data across a variety of species.

Each reviewer was instructed to confirm the selected data back to the secondary source -i.e., the database from which data on the spreadsheet were extracted. Each reviewer also tried to trace the data point back to a primary source – i.e., the original reference cited in the secondary source. If data could not be confirmed to a primary reference, the data was flagged. However, the ECOTOX Knowledgebase^2^ has a robust QC process ensuring data are verified using reliable source and reflect what was reported in the publication. Once quality assurance steps have been completed, the data are released to the ECOTOX Knowledgebase^2^. Therefore, confirming data to the ECOTOX Knowledgebase^2^ (i.e., secondary source) was equivalent to a primary source.

No study quality considerations were evaluated during the QC review. The workgroup did not review experimental design, statistical analyses, or data interpretation. Rather, the ecological hazard workgroup focused only on the data accuracy relative to the primary and secondary sources.

### Skin Sensitization and Skin/Eye Irritation Workgroup Review Approach

Skin sensitization and skin/eye irritation data were collected from publicly available sources and aggregated for review. Information standardized with the Global Harmonized System of Classification and Labeling of Chemicals (GHS)^131^ was extracted. The GHS classification codes -- including hazard codes or H-codes; numerical hazard categories; signal word codes; and classification, labeling, and packaging (CLP) hazard class -- were included and used for designating the chemicals as sensitizing or irritating. A single reviewer was assigned to review the skin and eye irritation data.

A reviewer was asked to verify data in the resulting spreadsheet for quality control of the programmatic data collection process. The reviewer performed an automated check of the data to ensure that transposition of secondary source data was correct by comparing numbers in the spreadsheet to the secondary source material. The reviewer then manually reviewed 10% of the data back to a primary source. This limited manual review was necessary owing to time and resource issues.

## Summary

In summary, the POC238 chemical substances were reviewed for transcription from primary and secondary sources into the database used for the PICS approach. This review did not take into account study quality or data validity, as that was determined to be part of an expert review process separate from this effort. For the PICs approach, data were deemed ‘acceptable’ if confirmed to a secondary source; primary source confirmation was not required. The case study developed methods for data aggregation, curation, and evaluation, as well as QA recommendations to efficiently review Type 1 datasets. The case highlighted various challenges in data quality and availability of primary sources in addition to the changing landscape of online resources worldwide and urgent need for specialized curation/quality resources, data quality tool(s), common data dictionary, process to store the documents for data provenance and quality flags for various data usage. These lessons learned have informed the QC process moving forward, storage and linking of secondary or primary sources to data records wherever available for data provenance, inclusion of data audit capability, development of quality flags to enable fit-for-purpose data aggregation, and the development of a QC tool for future use with large datasets as part of continuous curation effort.

118 https://www.epa.gov/sites/production/files/2018-09/documents/preprioritization_white_paper_9272018.pdf

119 https://cfpub.epa.gov/ecotox/

120 https://www.epa.gov/iris

121 https://www.epa.gov/chemical-research/rapid-chemical-exposure-and-dose-research

122 Wambaugh JF, Wang A, Dionisio KL, Frame A, Egeghy P, Judson R, Setzer RW. (2014). High throughput heuristics for prioritizing human exposure to environmental chemicals. Environmental Science and Technology 48(21):12760–7.

123 Ring CL, Arnot J, Bennett DH, Egeghy P, Fantke P, Huang L, Isaacs KK, Jolliet O, Phillips K, Price PS, Shin HM, Westgate JN, Setzer RW, Wambaugh JF. (2018). Consensus Modeling of Median Chemical Intake for the U.S. Population Based on Predictions of Exposure Pathways. Environmental Science and Technology. 53(2):719–732.

124 Mitro SD, Dodson RE, Singla V, Adamkiewicz G, Elmi AF, Tilly MK, and Zota AR. (2016). Consumer product chemicals in indoor dust: A quantitative meta-analysis of U.S. studies. Environmental Science and Technology 50: 13611–11.

125 Lehmann GM, LaKind JS, Davis MH, Hines EP, Marchitti SA, Alcala C, and Lorber C. (2018). Environmental chemicals in breast milk and formula: Exposure and risk assessment implications. Environmental Health Perspectives, 126: 96001.

126 https://www.epa.gov/chemical-data-reporting/2016-chemical-data-reporting-results

127 https://comptox.epa.gov/dashboard/downloads, CPDATdownload

128 https://comptox.epa.gov/dashboard/downloads, CPCATARCHIVE

129 Williams RV, DM DeMarini, LF Stankowski Jr, PA Escobar, E Zeiger, J Howe, R Elespuru, KP Cross. (2019). Are all bacterial strains required by OECD mutagenicity test guideline TG471 needed? Mutation Research 848:503081.

130 https://echa.europa.eu/

131 https://www.unece.org/trans/danger/publi/ghs/ghs_welcome_e.html