# Appendix B Detailed Information on Data Sources used in the PICS Approach

Sources | Human Hazard | Carcinogenicity | Genotoxicity | Ecological Hazard | Persistence and Bioaccumulation | Skin Sensitization and Skin/Eye | Exposure | Susceptible Populations | Description | Reference | URL
Compiled PODs, Toxicity Values and Cancer Classifications
Alaska Department of Environmental Conservation | | * | | | | | | | Cancer slope factors and unit risk compiled by State of Alaska | NA | https://dec.alaska.gov/spar/csp/guidance/cleanuplevels.pdf
Agency for Toxic Substances and Diseases Registry (ATSDR) | * | | | | | | | | NOAEL values derived from CDC / ATSDR risk assessments | NA | https://www.atsdr.cdc.gov/mrls/mrllist.asp
California Environmental Protection Agency, Office of Environmental Health Hazard Assessment (OEHHA) | | * | | | | | | | Cancer slope factors and unit risk compiled by State of California | NA | https://oehha.ca.gov/chemicals
California Environmental Protection Agency | | * | | | | | | | Cancer classifications from California EPA | NA | https://oehha.ca.gov/proposition-65/proposition-65-list
COSMOS | * | | * | * | | | | | Data compiled by the COSMOS project, a collaboration between the US FDA and Cosmetics Europe using integrated in silico models for the prediction of human repeated dose toxicity of COSMetics to Optimize Safety. | NA | http://www.cosmostox.eu/what/COSMOSdb/
Department of Energy (DOE) Wildlife Benchmarks | * | | | * | | | | | PODs from ecological risk assessments performed by DOE on both mammalian and aquatic species | Sample, B.E., Opresko, D.M., Suter, G.W. (1996) Toxicological Benchmarks for Wildlife: 1996 Revision. Springfield, VA: National Technical Information Service, U.S. Department of Commerce | https://rais.ornl.gov/documents/tm86r3.pdf
European Chemicals Agency (ECHA) eChemPortal | * | | * | * | | * | | | Data compiled by ECHA and made available through eChemPortal | NA | https://www.echemportal.org/echemportal/index.action
ECHA (IUCLID) | * | | | * | | | | | Data compiled by ECHA (European Chemicals Agency) and made available via an IUCLID data file | NA | https://echa.europa.eu/information-on-chemicals/registered-substances
European Union Reference Laboratory for Alternatives to Animal Testing (ECVAM EURL) Genotoxicity and Carcinogenicity Consolidated Database | | | * | | | | | | Genotoxicity data compiled by EURL ECCVAM | NA | https://data.europa.eu/euodp/data/dataset/jrc-eurl-ecvam-genotoxicity-carcinogenicity-ames
European Food Safety Authority (EFSA) | * | | | * | | | | | POD values compiled by EFSA (European Food Safety Agency) | NA | https://zenodo.org/record/1252752#.W-WNgDNReHs
EPA Health Effects Assessment Summary Tables (HEAST) | * | | | * | | | | | POD values compiled by EPA HEAST | NA | https://epa-heast.ornl.gov/heast.php
EPA High Production Volume Information System (HPVIS) | * | | | * | | | | | POD values compiled by EPA OPPT High Production Volume Information System | NA | Data was initially fully public, but access is now restricted. Data used here is a download from HPVIS from 2015
EPA Office of Pesticide Programs (OPP) Assessments | | * | | | | | | | Cancer slope factors and classifications compiled by EPA OPP | NA | https://iaspub.epa.gov/apex/pesticides/f?p=HHBP:home
EPA Office of Pollution Prevention and Toxics (OPPT) | * | | | | | | | | POD values from EPA OPPT Risk Assessment documents | NA | Data extracted from pdf files provided by OPPT, which should reflect data from ChemView https://chemview.epa.gov/chemview
Health Assessment Workspace Collaborative (HAWC) | * | | | * | | | | | POD values compiled from public HAWC projects | NA | https://hawcproject.org/
Health Canada | | * | | | | | | | Cancer slope factors, unit risk and classifications compiled by Health Canada | NA | http://publications.gc.ca/collections/collection_2012/sc-hc/H128-1-11-638-eng.pdf
Hazard Evaluation Support System (HESS) | * | | | | | | | | POD values compiled by HESS Japan (Hazard Evaluation Support System Integrated Platform, National Institute of Technology and Evaluation) | NA | http://www.nite.go.jp/en/chem/qsar/hess-e.html
International Agency for Research on Cancer (IARC) | | * | | | | | | | Cancer classifications derived by IARC | NA | https://monographs.iarc.fr/list-of-classifications-volumes/
Integrated Risk Information System (IRIS) | * | * | | | | | | | POD values, cancer slope factors, unit risk and cancer classifications from EPA IRIS | NA | https://cfpub.epa.gov/ncea/iris_drafts/simple_list.cfm
National Institute for Occupational Safety and Health (NIOSH) | | * | | | | | | | Cancer classifications compiled by NIOSH (CDC, National Institute for Occupational Safety and Health) | NA | https://www.cdc.gov/niosh/topics/cancer/npotocca.html
National Toxicology Program (NTP) Report on Carcinogens (ROC) | | * | | | | | | | Cancer classifications compiled by NTP (National Toxicology Program) | NA | https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#toc1
EPA Provisional Peer-Review Toxicity Values (PPRTV) [NCEA database] | * | | | | | | | | POD Values from EPA PPRTV documents, provided by EPA NCEA | NA | data provided by NCEA as an MS Access database
EPA Provisional Peer-Review Toxicity Values (PPRTV) [ORNL database] | * | * | | | | | | | POD Values from EPA PPRTV documents, cancer classifications extracted from ORNL PPRTV web site | NA | https://hhpprtv.ornl.gov/
Data compilations
EPA Chemical Data Reporting (CDR) | | | | | | | * | * | TSCA Chemical data reporting rule (CDR) production volume information | NA | https://www.epa.gov/chemical-data-reporting/2016-chemical-data-reporting-results
EPA Chemical And Product Categories (CPCat) | | | | | | | | * | Chemical and product categories | Dioniso Exploring consumer exposure pathways and patterns of use for chemicals in the environment, Tox. Reports vol 2, pp 28-237 (2015) | https://actor.epa.gov/cpcat/faces/home.xhtml
EPA Chemical and Products Database (CPDat) | | | | | | | | * | Chemical and product database | Dionisio KL, Phillips K, Price PS, Grulke CM, Williams A, Biryol D, Hong T, Isaacs KK. The Chemical and Products Database, a resource for exposure-relevant data on chemicals in consumer products. Sci Data. 2018 Jul 10;5:180125. doi: 10.1038/sdata.2018.125. PubMed PMID: 29989593; PubMed Central PMCID: PMC603884729989593 | https://www.epa.gov/chemical-research/chemical-and-products-database-cpdat
EPA ECOTOXicology knowledgebase (ECOTOX) | * | | | * | | | | | EPA ECOTOX database. Data imported to ToxValDB | NA | https://cfpub.epa.gov/ecotox/
EPA Toxicity Forecaster (ToxCast) v3.0 | * | | | | | | | | High-throughput data for a variety of high level cellular responses. | Judson In vitro Screening of Environmental Chemicals for Targeted Testing Prioritization: The ToxCast Project, Environmental Health Perspectives, volume 118, p 485 | https://figshare.com/articles/ToxCast_Database_invitroDB_/6062623/2
EPA Toxicity Reference Database (ToxRefDB) | * | | | | | | | | POD values from EPA ToxRefDB | Watford, S., A. Adrian, J. Wignall, J. Brown, AND M. Martin. ToxRefDB 2.0: Improvements in Capturing Qualitative and Quantitative Data from in vivo Toxicity Studies (SOT). Presented at SOT Annual Meeting, Baltimore, MD, March 12 - 16, 2017. 10.23645/epacomptox.5178622 | https://epa.figshare.com/articles/Animal_Toxicity_Studies_Effects_and_Endpoints_Toxicity_Reference_Database_-_ToxRefDB_files_/6062545
Istituto Superiore di Sanita Chemical Toxicity database on long-term carcinogenicity bioassay on rodents (rat and mouse) (ISSCAN) | | | * | | | | | | Database of genotoxicity data compiled by Istituto Superiore di Sanita (ISS), Italy | Begnini “a novel approach: chemical relational databases,and the role of the ISScaN database on assessing chemical carcinogenicity”, Ann 1st super sAnItà 2008 \| Vol. 44, no. 1: 48–56 | http://old.iss.it/publ/anna/2008/1/44148.pdf
Toxicology Data Network (TOXNET) | | | * | | | | | | Genetoxicity data downloaded from National Library of Medicine (NLM) TOXNET | NA | https://toxnet.nlm.nih.gov/newtoxnet/genetox.htm
Prediction Models
EPA Tool for High-Throughput Toxicokinetics (HTTK) | * | | | | | | | | High-throughput toxicokinetic data and models used to predict in vivo administered equivalent doses from in vitro bioactive concentrations | Pearce “httk: R Package for High-Throughput Toxicokinetics”, J Stat Softw. 2017 Jul 17; 79(4): 1–26. doi: 10.18637/jss.v079.i04 30220889 | https://cran.r-project.org/web/packages/httk/index.html (data are in the RData within the package)
EPA Exposure Forecaster (ExpoCast) Systemic Empirical Evaluation of Models 3 (SEEM3) | | | | | | | * | | Systematic Empirical Evaluation of Models (SEEM) framework includes calibration and evaluation of the models using chemical concentrations found in blood and urine samples from the National Health and Nutrition Examination Study. | Ring , “Consensus Modeling of Median Chemical Intake for the U.S. Population Based on Predictions of Exposure Pathways”, Environ. Sci. Technol., 2019, 53 (2), pp 719–732 DOI: 10.1021/acs.est.8b04056 30516957 | https://pubs.acs.org/doi/10.1021/acs.est.8b04056
Ecological Structure Activity Relationship Prediction Model (ECOSAR) | | | | * | | | | | SAR model to predict aquatic PODs | NA | https://www.epa.gov/tsca-screening-tools/ecological-structure-activity-relationships-ecosar-predictive-model
EPI Suite | | | | | * | | | | QSAR software to estimate physicochemical and fate and transport properties | | https://www.epa.gov/tsca-screening-tools/download-epi-suitetm-estimation-program-interface-v411
EPA Toxicity Estimation Software Tool (TEST) | | | * | | | * | | | Skin and Eye irritation and sensitization data derived from GHS documents, and genotoxicity QSAR model | Vegosen and Martin, “An automated framework for compiling and integrating chemical hazard data”, Clean Tech. Environ. Policy, 2020, 22, pp. 441–458 DOI 10.1007/s10098-019-01795-w | https://www.epa.gov/chemical-research/toxicity-estimation-software-tool-test
OPEn structure–activity/property Relationship App (OPERA) | | | | | * | | | | OPEn structure–activity/property Relationship App for predicting physicochemical and environmental fate properties | Mansouri “OPERA models for predicting physicochemical properties and environmental fate endpoints”, Journal of Cheminformatics 2018 10:10 29520515 | https://icheminf.biomedcentral.com/articles/10.1186/s13321-018-0263-1
ToxTree | * | | | | | | | | Toxic Hazard Estimation by decision tree approach used to predict threshold of toxicological concern (TTC) | Patlewicz, G., (2008). “An evaluation of the implementation of the Cramer classification scheme in the Toxtree software.” SAR QSAR Environ Res 19(5–6): 495–524.18853299 | http://toxtree.sourceforge.net/
World Health Organization (WHO) International Programme on Chemical Safety (IPCS) | * | | | | | | | | Acute toxicity values from WHO Pesticides Classification | See URL | http://www.who.int/ipcs/publications/pesticides_hazard_2009.pdf
Publications
Arnot and Gobas (2006) | | | | | * | | | | BAF and BCF values compiled from experimental studies | Arnot and Gobas, “A review of bioconcentration factor (BCF) and bioaccumulation factor (BAF) assessments for organic chemicals in aquatic organisms”, Environmental Reviews, 2006, 14(4): 257–297, 10.1139/a06-005 | https://www.nrcresearchpress.com/doi/10.1139/a06-005#.XL9OkehKg2w
Chiu et al. (2018) | * | | | | | | | | POD values compiled by Chiu et al. | Chiu W, “Beyond the RfD: Broad Application of a Probabilistic Approach to Improve Chemical Dose–Response Assessments for Noncancer Effects”, Env. Health. Persp. Vol 126 (2018) | https://doi.org/10.1289/EHP3368
Wignall et al. (2014) | * | | | | | | | | BMD values compiled or derived by Wignall et al. | Wignall J. “Standardizing Benchmark Dose Calculations to Improve Science-Based Decisions in Human Health Assessments”, Env. Health Persp. Vol. 22 p 499 (2014) | https://ehp.niehs.nih.gov/doi/10.1289/ehp.1307539