# Appendix A Proof-of-Concept (POC) Subset of the Non-confidential TSCA Active Inventory

CASRN | DTXSID | PREFERRED_NAME
156-60-5 | DTXSID7024031 | (E)-1,2-Dichloroethylene
79-33-4 | DTXSID6034689 | (S)-2-Hydroxypropionic acid
54464-59-4 | DTXSID5052200 | 1-(1,2,3,4,5,6,7,8-Octahydro-2,3,5,5-tetramethyl-2-naphthyl)ethan-1-one
68155-66-8 | DTXSID9052397 | 1-(1,2,3,5,6,7,8,8a-Octahydro-2,3,8,8-tetramethyl-2-naphthyl)ethan-1-one
68155-67-9 | DTXSID6041923 | 1-(2,3,8,8-Tetramethyl-1,2,3,4,6,7,8,8a-octahydronaphthalen-2-yl)ethanone
79-34-5 | DTXSID7021318 | 1,1,2,2-Tetrachloroethane
79-00-5 | DTXSID5021380 | 1,1,2-Trichloroethane
75-34-3 | DTXSID1020437 | 1,1-Dichloroethane
1163-19-5 | DTXSID9020376 | 1,1’-Oxybis[2,3,4,5,6-pentabromobenzene]
110-98-5 | DTXSID7026863 | 1,1’-Oxybis-2-propanol
96-18-4 | DTXSID9021390 | 1,2,3-Trichloropropane
120-82-1 | DTXSID0021965 | 1,2,4-Trichlorobenzene
3194-55-6 | DTXSID4027527 | 1,2,5,6,9,10-Hexabromocyclododecane
106-93-4 | DTXSID3020415 | 1,2-Dibromoethane
95-50-1 | DTXSID6020430 | 1,2-Dichlorobenzene
107-06-2 | DTXSID6020438 | 1,2-Dichloroethane
78-87-5 | DTXSID0020448 | 1,2-Dichloropropane
6920-22-5 | DTXSID40863959 | 1,2-Hexanediol
57-55-6 | DTXSID0021206 | 1,2-Propylene glycol
106-99-0 | DTXSID3020203 | 1,3-Butadiene
99-65-0 | DTXSID9024065 | 1,3-Dinitrobenzene
102-06-7 | DTXSID3025178 | 1,3-Diphenylguanidine
106-46-7 | DTXSID1020431 | 1,4-Dichlorobenzene
123-91-1 | DTXSID4020533 | 1,4-Dioxane
106-94-5 | DTXSID6021874 | 1-Bromopropane
71-36-3 | DTXSID1021740 | 1-Butanol
88-73-3 | DTXSID0020280 | 1-Chloro-2-nitrobenzene
100-00-5 | DTXSID5020281 | 1-Chloro-4-nitrobenzene
661-19-8 | DTXSID4027286 | 1-Docosanol
629-96-9 | DTXSID0027272 | 1-Eicosanol
36653-82-4 | DTXSID4027991 | 1-Hexadecanol
112-92-5 | DTXSID8026935 | 1-Octadecanol
111-87-5 | DTXSID7021940 | 1-Octanol
118-96-7 | DTXSID7024372 | 2,4,6-Trinitrotoluene
732-26-3 | DTXSID2021311 | 2,4,6-Tris(tert-butyl)phenol
51-28-5 | DTXSID0020523 | 2,4-Dinitrophenol
121-14-2 | DTXSID0020529 | 2,4-Dinitrotoluene
108-31-6 | DTXSID7024166 | 2,5-Furandione
96-29-7 | DTXSID1021821 | 2-Butanone oxime
110-44-1 | DTXSID3021277 | 2E,4E-Hexadienoic acid
183658-27-7 | DTXSID9052686 | 2-Ethylhexyl 2,3,4,5-tetrabromobenzoate
149-30-4 | DTXSID1020807 | 2-Mercaptobenzothiazole
109-86-4 | DTXSID5024182 | 2-Methoxyethanol
78-83-1 | DTXSID0021759 | 2-Methyl-1-propanol
534-52-1 | DTXSID1022053 | 2-Methyl-4,6-dinitrophenol
55583-69-2 | DTXSID70873187 | 2-Methylallyl alcohol ethoxylate
88-74-4 | DTXSID1025726 | 2-Nitroaniline
79-94-7 | DTXSID1026081 | 3,3’,5,5’-Tetrabromobisphenol A
91-94-1 | DTXSID6020432 | 3,3’-Dichlorobenzidine
612-83-9 | DTXSID1020433 | 3,3’-Dichlorobenzidine dihydrochloride
591-35-5 | DTXSID2025006 | 3,5-Dichlorophenol
4435-53-4 | DTXSID2052106 | 3-Methoxybutyl acetate
99-08-1 | DTXSID5021831 | 3-Nitrotoluene
140-66-9 | DTXSID9022360 | 4-(1,1,3,3-Tetramethylbutyl)phenol
17540-75-9 | DTXSID8029315 | 4-(Butan-2-yl)-2,6-di-tert-butylphenol
16090-02-1 | DTXSID0027777 | 4,4’-Bis(2-morpholino-4-anilino-s-triazinyl-6-amino)stilbene-2,2’-disulfonic acid disodium salt
101-14-4 | DTXSID5020865 | 4,4’-Methylenebis(2-chloroaniline)
80-51-3 | DTXSID7026499 | 4,4’-Oxybis(benzenesulfohydrazide)
101-80-4 | DTXSID0021094 | 4,4’-Oxydianiline
136-85-6 | DTXSID1038743 | 5-Methyl-1H-benzotriazole
51-52-5 | DTXSID5021209 | 6-Propyl-2-thiouracil
75-07-0 | DTXSID5039224 | Acetaldehyde
103-90-2 | DTXSID2020006 | Acetaminophen
79-06-1 | DTXSID5020027 | Acrylamide
79-10-7 | DTXSID0039229 | Acrylic acid
107-13-1 | DTXSID5020029 | Acrylonitrile
3825-26-1 | DTXSID8037708 | Ammonium perfluorooctanoate
62-53-3 | DTXSID8020090 | Aniline
NOCAS_872414 | DTXSID30872414 | Antimony & Antimony Compounds
NOCAS_872415 | DTXSID90872415 | Arsenic & Arsenic Compounds
137-66-6 | DTXSID3041611 | Ascorbyl palmitate
50-78-2 | DTXSID5020108 | Aspirin
1912-24-9 | DTXSID9020112 | Atrazine
25057-89-0 | DTXSID0023901 | Bentazone
1302-78-9 | DTXSID6030782 | Bentonite
71-43-2 | DTXSID3039242 | Benzene
65-85-0 | DTXSID6020143 | Benzoic acid
119-61-9 | DTXSID0021961 | Benzophenone
85-68-7 | DTXSID3020205 | Benzyl butyl phthalate
26040-51-7 | DTXSID7027887 | Bis(2-ethylhexyl) tetrabromophthalate
103-23-1 | DTXSID0020606 | Bis(2-ethylhexyl)hexanedioate
80-05-7 | DTXSID7020182 | Bisphenol A
75-25-2 | DTXSID1021374 | Bromoform
128-37-0 | DTXSID2020216 | Butylated hydroxytoluene
17852-99-2 | DTXSID2066270 | C.I. Pigment Red 52, calcium salt (1:1)
5567-15-7 | DTXSID1021453 | C.I. Pigment Yellow 83
7440-43-9 | DTXSID1023940 | Cadmium
NOCAS_872417 | DTXSID10872417 | Cadmium & Cadmium Compounds
58-08-2 | DTXSID0020232 | Caffeine
62-54-4 | DTXSID0020234 | Calcium acetate
299-28-5 | DTXSID2029618 | Calcium D-gluconate
105-60-2 | DTXSID4020240 | Caprolactam
10605-21-7 | DTXSID4024729 | Carbendazim
56-23-5 | DTXSID8020250 | Carbon tetrachloride
513-77-9 | DTXSID1029623 | Carbonic acid, barium salt (1:1)
1698-60-8 | DTXSID3034872 | Chloridazon
108-90-7 | DTXSID4020298 | Chlorobenzene
143-28-2 | DTXSID0022010 | cis-Oleyl alcohol
77-92-9 | DTXSID3020332 | Citric acid
1702-17-6 | DTXSID9029221 | Clopyralid
NOCAS_872419 | DTXSID30872419 | Cobalt & Cobalt Compounds
7646-79-9 | DTXSID9040180 | Cobalt chloride
64-86-8 | DTXSID5024845 | Colchicine
8001-58-9 | DTXSID2023987 | Creosote
420-04-2 | DTXSID9034490 | Cyanamide
NOCAS_872420 | DTXSID40872420 | Cyanide salts
1222-05-5 | DTXSID8027373 | Cyclopenta[g]-2-benzopyran, 1,3,4,6,7,8-hexahydro-4,6,6,7,8,8-hexamethyl-
134-62-3 | DTXSID2021995 | DEET
50-02-2 | DTXSID3020384 | Dexamethasone
81-13-0 | DTXSID3022906 | Dexpanthenol
50-70-4 | DTXSID5023588 | D-Glucitol
526-95-4 | DTXSID8027169 | D-Gluconic acid
50-99-7 | DTXSID7022910 | D-Glucose
117-81-7 | DTXSID5020607 | Di(2-ethylhexyl) phthalate
131-17-9 | DTXSID7020392 | Diallyl phthalate
109-43-3 | DTXSID1041847 | Dibutyl decanedioate
84-74-2 | DTXSID2021781 | Dibutyl phthalate
75-09-2 | DTXSID0020868 | Dichloromethane
62-73-7 | DTXSID5020449 | Dichlorvos
99-30-9 | DTXSID2020426 | Dicloran
84-61-7 | DTXSID5025021 | Dicyclohexyl phthalate
105-53-3 | DTXSID7021863 | Diethyl propanedioate
111-77-3 | DTXSID3025049 | Diethylene glycol monomethyl ether
35367-38-5 | DTXSID1024049 | Diflubenzuron
84-69-5 | DTXSID9022522 | Diisobutyl phthalate
26761-40-0 | DTXSID4025082 | Diisodecyl phthalate
28553-12-0 | DTXSID4022521 | Diisononyl phthalate
60-51-5 | DTXSID7020479 | Dimethoate
108-59-8 | DTXSID4029145 | Dimethyl malonate
108-01-0 | DTXSID2020505 | Dimethylaminoethanol
117-84-0 | DTXSID1021956 | Di-n-octyl phthalate
25265-71-8 | DTXSID0027856 | Dipropylene glycol
88917-22-0 | DTXSID4029062 | Dipropyleneglycol methyl ether acetate
330-54-1 | DTXSID0020446 | Diuron
69-65-8 | DTXSID1023235 | D-Mannitol
112-85-6 | DTXSID3026930 | Docosanoic acid
577-11-7 | DTXSID8022959 | Docusate sodium
9004-32-4 | DTXSID2020555 | Edifas B
759-94-4 | DTXSID1024091 | EPTC
64-17-5 | DTXSID9020584 | Ethanol
91-53-2 | DTXSID9020582 | Ethoxyquin
141-78-6 | DTXSID1022001 | Ethyl acetate
100-41-4 | DTXSID3020596 | Ethylbenzene
107-21-1 | DTXSID8020597 | Ethylene glycol
110-71-4 | DTXSID0025286 | Ethylene glycol dimethyl ether
75-21-8 | DTXSID0020600 | Ethylene oxide
60168-88-9 | DTXSID2032390 | Fenarimol
50-00-0 | DTXSID7020637 | Formaldehyde
446-72-0 | DTXSID5022308 | Genistein
106-24-1 | DTXSID8026727 | Geraniol
90-80-2 | DTXSID0026549 | Gluconolactone
111-30-8 | DTXSID6025355 | Glutaraldehyde
25637-99-4 | DTXSID8025383 | Hexabromocyclododecane
87-68-3 | DTXSID7020683 | Hexachloro-1,3-butadiene
118-74-1 | DTXSID2020682 | Hexachlorobenzene
51235-04-2 | DTXSID4024145 | Hexazinone
123-31-9 | DTXSID7020716 | Hydroquinone
54464-57-2 | DTXSID7031290 | Isocyclemone E
97-54-1 | DTXSID7022413 | Isoeugenol
78-79-5 | DTXSID2020761 | Isoprene
1332-58-7 | DTXSID6049640 | Kaolin
50-21-5 | DTXSID7023192 | Lactic acid
63-42-3 | DTXSID2023193 | Lactose
52-90-4 | DTXSID8022876 | L-Cysteine
NOCAS_872421 | DTXSID00872421 | Lead & Lead Compounds
63-68-3 | DTXSID5040548 | L-Methionine
NOCAS_872422 | DTXSID60872422 | Long-chain chlorinated paraffins (C18-20)
6915-15-7 | DTXSID0027640 | Malic acid
NOCAS_872423 | DTXSID20872423 | Medium-chain chlorinated paraffins (C14-17)
7487-94-7 | DTXSID5020811 | Mercuric chloride
67-56-1 | DTXSID2021731 | Methanol
625-45-6 | DTXSID1031591 | Methoxyacetic acid
74-83-9 | DTXSID8020832 | Methyl bromide
9004-67-5 | DTXSID1036919 | Methyl cellulose
99-76-3 | DTXSID4022529 | Methylparaben
NOCAS_872424 | DTXSID80872424 | Molybdenum & Molybdenum Compounds
31138-65-5 | DTXSID7027966 | Monosodium D-glucoheptonate
108-38-3 | DTXSID6026298 | m-Xylene
99-97-8 | DTXSID0021832 | N,N,4-Trimethylaniline
91-20-3 | DTXSID8020913 | Naphthalene
NOCAS_872425 | DTXSID40872425 | Nickel & Nickel Compounds
872-50-4 | DTXSID6020856 | N-Methyl-2-pyrrolidone
86-30-6 | DTXSID6021030 | N-Nitrosodiphenylamine
25154-52-3 | DTXSID3021857 | n-Nonylphenol
95-48-7 | DTXSID8021808 | o-Cresol
1843-05-6 | DTXSID9027441 | Octabenzone
556-67-2 | DTXSID7027205 | Octamethylcyclotetrasiloxane
124-07-2 | DTXSID3021645 | Octanoic acid
112-80-1 | DTXSID1025809 | Oleic acid
95-47-6 | DTXSID3021807 | o-Xylene
133-49-3 | DTXSID3044540 | Pentachlorobenzenethiol
87-86-5 | DTXSID7021106 | Pentachlorophenol
3296-90-0 | DTXSID9020164 | Pentaerythritol dibromide
375-73-5 | DTXSID5030030 | Perfluorobutanesulfonic acid
335-76-2 | DTXSID3031860 | Perfluorodecanoic acid
335-67-1 | DTXSID8031865 | Perfluorooctanoic acid
108-95-2 | DTXSID5021124 | Phenol
85-44-9 | DTXSID2021159 | Phthalic anhydride
1918-02-1 | DTXSID1021160 | Picloram
81-33-4 | DTXSID9052555 | Pigment Violet 29
6528-34-3 | DTXSID0052336 | Pigment Yellow 65
298-14-6 | DTXSID0021177 | Potassium bicarbonate
299-27-4 | DTXSID7029617 | Potassium D-gluconate
29420-49-3 | DTXSID3037707 | Potassium perfluorobutanesulfonate
106-42-3 | DTXSID2021868 | p-Xylene
108-46-3 | DTXSID2021238 | Resorcinol
68-26-8 | DTXSID3023556 | Retinol
127-47-9 | DTXSID6021240 | Retinol acetate
90-02-8 | DTXSID1021792 | Salicylaldehyde
122-34-9 | DTXSID4021268 | Simazine
497-19-8 | DTXSID1029621 | Sodium carbonate
4418-26-2 | DTXSID7026029 | Sodium dehydroacetate
527-07-1 | DTXSID7027170 | Sodium D-gluconate
7632-00-0 | DTXSID0020941 | Sodium nitrite
1344-09-8 | DTXSID9029647 | Sodium silicate
10102-17-7 | DTXSID6044197 | Sodium thiosulfate, pentahydrate
111-01-3 | DTXSID0046513 | Squalane
100-42-5 | DTXSID2021284 | Styrene
57-50-1 | DTXSID2021288 | Sucrose
994-05-8 | DTXSID8024521 | tert-Amyl methyl ether
127-18-4 | DTXSID2021319 | Tetrachloroethylene
58-55-9 | DTXSID5021336 | Theophylline
62-55-5 | DTXSID9021340 | Thioacetamide
137-26-8 | DTXSID5021332 | Thiram
7772-99-8 | DTXSID8021351 | Tin(II) chloride
126-73-8 | DTXSID3021986 | Tributyl phosphate
1461-22-9 | DTXSID3027403 | Tributyltin chloride
79-01-6 | DTXSID0021383 | Trichloroethylene
101-20-2 | DTXSID4026214 | Triclocarban
55335-06-3 | DTXSID0032497 | Triclopyr
77-93-0 | DTXSID0040701 | Triethyl citrate
2451-62-9 | DTXSID4026262 | Triglycidyl isocyanurate
115-86-6 | DTXSID1021952 | Triphenyl phosphate
68937-41-7 | DTXSID4028880 | Triphenyl phosphates isopropylated
24800-44-0 | DTXSID7027837 | Tripropylene glycol
55934-93-5 | DTXSID8042503 | Tripropylene glycol butyl ether
115-96-8 | DTXSID5021411 | Tris(2-chloroethyl) phosphate
75-01-4 | DTXSID8021434 | Vinyl chloride