# PEER REVIEW PLAN

Title: | A Proof-of-Concept Case Study Integrating Publicly Available Information to Screen Candidates for Chemical Prioritization under TSCA
Purpose/Objective: | Regulatory agencies world-wide are looking to efficiently integrate information on chemical substances in order to inform priorities for decisions and data requests. This document updates the long-term strategy described in the Working Approach and presents the Public Information Curation and Synthesis (PICS) approach that integrates publicly-available hazard, exposure, persistence, and bioaccumulation information for chemical substances. This approach is not designed to replace the prioritization process described in TSCA but aims to increase efficiency and focus expert review on substances that may have a greater potential for selection as a high- or low-priority candidate.
Product Completion Date (Projected): | 03/01/2021
OMB Category: | Influential
Peer Review Leader: | Rebecca Daniels; email: daniels.rebecca@epa.gov

External Peer Review Mechanism: | Letter Review by Independent Subject Experts
Peer Review Expected to Begin: | 1st Quarter, Fiscal Year 2021
| EPA’s Fiscal Years run from October to September.; Quarters for Fiscal Year 2021:; 1st: October - December, 2020; 2nd: January - March, 2021; 3rd: April - June, 2021; 4th: July - September, 2021

Was a deferral to peer review invoked? | No
Will an alternative peer review process be employed? | No
Number of Peer Reviewers | 4 to 10
Primary Disciplines needed in the review: | Toxicology-General
Who will select the reviewers? | a Contractor
Will the public, including scientific or professional societies be asked to nominate peer reviewers? | No
Will public nominations be allowed through the Peer Review Agenda? | No
Will there be opportunity for public comment on the product? | No
Will the Agency provide significant and relevant public comments to the peer reviewers before they conduct their review? | No
Will the review be a panel, conducted in public? | No
Will public comments be allowed at the panel review? | No