# List of Abbreviations and Acronyms

AD: Applicability Domain
ATSDR: Agency for Toxic Substances and Disease Registry (CDC)
BAF: Bioaccumulation Factor
BCF: Bioconcentration Factor
BER: Bioactivity-to-Exposure Ratio
CA: Chromosomal Aberration
CDC: Centers for Disease Control and Prevention
CMP: (Canadian) Chemicals Management Plan
CPCat: Chemical and Product Categories (database)
CPDat: Chemical and Product Database
CTS: Chemical Transformation Simulator (US EPA ORD)
DSSTox: Distributed Structure-Searchable Toxicity Database
DTXSIDs: DSSTox Substance Identifiers
ECHA: European Chemicals Agency
EcoSAR: Ecological Structure Activity Relationships
EFSA: European Food Safety Authority
EPA: US Environmental Protection Agency
ExpoCast: Exposure Forecasting
EUSES: European Union System for Evaluation of Substances
FDA: Food and Drug Administration
GHS: Globally Harmonized System of Classification and Labeling of Chemicals
HER: Human Hazard-to-Exposure Ratio
HESS: Hazard Evaluation Support System
HPVIS: High Production Volume Information System
HSDB: Hazardous Substances Data Bank
IAM: Information Availability Metric
IARC: International Agency for Research on Cancer
IG: Information Gathering
IRIS: Integrated Risk Information System
LLNA: Local Lymph Node Assay
MNT: Micronucleus Test
NAMs: New Approach Methods
NIOSH: National Institute for Occupational Safety and Health (CDC)
NTP: National Toxicology Program
OCSPP: Office of Chemical Safety and Pollution Prevention (OCSPP)
OECD: Organization for Economic Cooperation and Development
OPP: Office of Pesticide Programs (US EPA)
OPPT: Office of Pollution Prevention and Toxics (US EPA)
ORD: Office of Research and Development (US EPA)
PECs: Predicted Exposure Concentrations
PICS: Public Infonnation Curation and Synthesis
PNECs: Predicted no Effect Concentrations
POD: Points-of-Departure
Pov: Overall Chemical Persistence
PPRTV: Provisional Peer-Reviewed Toxicity Values
QC: Quality Control
QA: Quality Assurance
QSAR: Quantitative Structure-Activity Relationship
ROC: Report on Carcinogenesis (NTP)
SCIL: Safer Chemical Ingredients List
SDM: Scientific Domain Metric
SEEM: Systematic Empirical Evaluation of Models
TER: TTC-to-Exposure Ratio
TEST: Toxicity Estimation Software Tool (US EPA)
TSCA: Toxic Substances Control Act
TSCA10: First Ten TSCA Work Plan Chemical Substances Selected for Evaluation
TSCA90: Chemical Substances from the 2014 Update to the TSCA Work Plan
POC238: 238 Chemical Substances Selected for the POC Case Study
TTC: Threshold of Toxicological Concern
UVCBs: Unknown or Variable Composition, Complex Reaction Products and Biological Materials
WHO: World Health Organization
WOE: Weight-of-Evidence