# References

15 USC §2601, 2016. 15 USC §2601: Findings, policy, and intent [WWW Document]. URL https://uscode.house.gov/view.xhtml?req=(title:15%20section:2601%20edition:prelim) (accessed 11.2.22).
21 CFR § 58, n.d. CFR - Code of Federal Regulations Title 21 [WWW Document]. URL https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?CFRPart=58 (accessed 11.3.22).
40 CFR § 160, n.d. CFR - Code of Federal Regulations Title 40 [WWW Document]. URL https://www.ecfr.gov/current/title-40/chapter-I/subchapter-E/part-160 (accessed 5.9.23).
40 CFR § 792, n.d. CFR - Code of Federal Regulations Title 40 [WWW Document]. URL https://www.ecfr.gov/current/title-40/chapter-I/subchapter-R/part-792 (accessed 5.9.23).
42 U.S.C 285l-3, 2000. ICCVAM Authorization Act of 2000 [WWW Document]. 42 U.S.C. 285l-3 Public Law 106–545. URL https://www.congress.gov/bill/106th-congress/house-bill/4281/text (accessed 5.9.23).
Allen, D.G., Rooney, J., Kleinstreuer, N., Lowit, A., Perron, M., 2021. Retrospective analysis of dermal absorption triple pack data. ALTEX - Alternatives to animal experimentation 38, 463–476. 10.14573/altex.2101121 33712859
Browne, P., Delrue, N., Gourmelon, A., 2019. Regulatory use and acceptance of alternative methods for chemical hazard identification. Current Opinion in Toxicology 15, 18–25.
Browne, P., Kleinstreuer, N.C., Ceger, P., Deisenroth, C., Baker, N., Markey, K., Thomas, R.S., Judson, R.J., Casey, W., 2018. Development of a curated Hershberger database. Reproductive Toxicology 81, 259–271. 10.1016/j.reprotox.2018.08.016 30205136
Ceger, P., Allen, D., Blankinship, A., Choksi, N., Daniel, A., Eckel, W.P., Hamm, J., Harwood, D.E., Johnson, T., Kleinstreuer, N., Sprankle, C.S., Truax, J., Lowit, M., 2023. Evaluation of the fish acute toxicity test for pesticide registration. Regulatory Toxicology and Pharmacology 139, 105340. 10.1016/j.yrtph.2023.105340 36702196
Ceger, P., Garcia-Reyero Vinas, N., Allen, D., Arnold, E., Bloom, R., Brennan, J.C., Clarke, C., Eisenreich, K., Fay, K., Hamm, J., Henry, P.F.P., Horak, K., Hunter, W., Judkins, D., Klein, P., Kleinstreuer, N., Koehrn, K., LaLone, C.A., Laurenson, J.P., Leet, J.K., Lowit, A., Lynn, S.G., Norberg-King, T., Perkins, E.J., Petersen, E.J., Rattner, B.A., Sprankle, C.S., Steeger, T., Warren, J.E., Winfield, S., Odenkirchen, E., 2022. Current ecotoxicity testing needs among selected U.S. federal agencies. Regulatory Toxicology and Pharmacology 133, 105195. 10.1016/j.yrtph.2022.105195 35660046
Chang, X., Tan, Y.-M., Allen, D.G., Bell, S., Brown, P.C., Browning, L., Ceger, P., Gearhart, J., Hakkinen, P.J., Kabadi, S.V., Kleinstreuer, N.C., Lumen, A., Matheson, J., Paini, A., Pangburn, H.A., Petersen, E.J., Reinke, E.N., Ribeiro, A.J.S., Sipes, N., Sweeney, L.M., Wambaugh, J.F., Wange, R., Wetmore, B.A., Mumtaz, M., 2022. IVIVE: Facilitating the use of in vitro toxicity data in risk assessment and decision making. Toxics 10, 232. 10.3390/toxics10050232 35622645
Chiu, W.A., Wright, F.A., Rusyn, I., 2017. A tiered, Bayesian approach to estimating of population variability for regulatory decision-making. ALTEX 34, 377–388. 10.14573/altex.1608251 27960008
Choksi, N.Y., Truax, J., Layton, A., Matheson, J., Mattie, D., Varney, T., Tao, J., Yozzo, K., McDougal, A.J., Merrill, J., Lowther, D., Barroso, J., Linke, B., Casey, W., Allen, D., 2019. United States regulatory requirements for skin and eye irritation testing. Cutan Ocul Toxicol 38, 141–155. 10.1080/15569527.2018.1540494 30418044
Church, R.J., Gatti, D.M., Urban, T.J., Long, N., Yang, X., Shi, Q., Eaddy, J.S., Mosedale, M., Ballard, S., Churchill, G.A., Navarro, V., Watkins, P.B., Threadgill, D.W., Harrill, A.H., 2015. Sensitivity to hepatotoxicity due to epigallocatechin gallate is affected by genetic background in diversity outbred mice. Food Chem Toxicol 76, 19–26. 10.1016/j.fct.2014.11.008 25446466
Clippinger, A.J., Raabe, H.A., Allen, D.G., Choksi, N.Y., van der Zalm, A.J., Kleinstreuer, N.C., Barroso, J., Lowit, A.B., 2021. Human-relevant approaches to assess eye corrosion/irritation potential of agrochemical formulations. Cutan Ocul Toxicol 40, 145–167. 10.1080/15569527.2021.1910291 33830843
Corley, R.A., Kuprat, A.P., Suffield, S.R., Kabilan, S., Hinderliter, P.M., Yugulis, K., Ramanarayanan, T.S., 2021. New approach methodology for assessing inhalation risks of a contact respiratory cytotoxicant: computational fluid dynamics-based aerosol dosimetry modeling for cross-species and in vitro comparisons. Toxicological Sciences 182, 243–259. 10.1093/toxsci/kfab062 34077545
CPSC, 2020. Proposed Guidance for Industry and Test Method Developers: CPSC Staff Evaluation of Alternative Test Methods and Integrated Testing Approaches and Data Generated from Such Methods to Support FHSA Labeling Requirements [WWW Document]. URL https://www.regulations.gov/document/CPSC-2021-0006-0001 (accessed 5.4.22).
CPSC, 2012. Recommended Procedures Regarding the CPSC’s Policy on Animal Testing [WWW Document]. URL https://www.cpsc.gov/Business--Manufacturing/Testing-Certification/Recommended-Procedures-Regarding-the-CPSCs-Policy-on-Animal-Testing (accessed 5.4.22).
Crofton, K.M., Mundy, W.R., 2021. External Scientific Report on the Interpretation of Data from the Developmental Neurotoxicity In Vitro Testing Assays for Use in Integrated Approaches for Testing and Assessment. EFSA Supporting Publications 18, 6924E. 10.2903/sp.efsa.2021.EN-6924
Daniel, A.B., Strickland, J., Allen, D., Casati, S., Zuang, V., Barroso, J., Whelan, M., Régimbald-Krnel, M.J., Kojima, H., Nishikawa, A., Park, H.-K., Lee, J.K., Kim, T.S., Delgado, I., Rios, L., Yang, Y., Wang, G., Kleinstreuer, N., 2018. International regulatory requirements for skin sensitization testing. Regul Toxicol Pharmacol 95, 52–65. 10.1016/j.yrtph.2018.03.003 29518484
Deisenroth, C., Soldatow, V.Y., Ford, J., Stewart, W., Brinkman, C., LeCluyse, E.L., MacMillan, D.K., Thomas, R.S., 2020. Development of an In Vitro Human Thyroid Microtissue Model for Chemical Screening. Toxicological Sciences 174, 63–78. 10.1093/toxsci/kfz238 31808822
Dumont, J., Euwart, D., Mei, B., Estes, S., Kshirsagar, R., 2016. Human cell lines for biopharmaceutical manufacturing: history, status, and future perspectives. Crit Rev Biotechnol 36, 1110–1122. 10.3109/07388551.2015.1084266 26383226
Elliott, J.T., Rösslein, M., Song, N.W., Toman, B., Ovaskainen, A.K.-, Maniratanachote, R., Salit, M.L., Petersen, E.J., Sequeira, F., Romsos, E., Kim, S.J., Lee, J., Moos, N.R. von, Rossi, F., Hirsch, C., Krug, H.F., Suchaoin, W., Wick, P., 2017. Toward achieving harmonization in a nanocytotoxicity assay measurement through an interlaboratory comparison study. ALTEX - Alternatives to animal experimentation 34, 201–218. 10.14573/altex.1605021 27684074
EPA, 2023. Availability of New Approach Methodologies (NAMs) in the Endocrine Disruptor Screening Program (EDSP) [WWW Document]. URL https://www.regulations.gov/document/EPA-HQ-OPP-2021-0756-0002 (accessed 2.20.23).
EPA, 2021a. EPA New Approach Methods Work Plan [WWW Document]. URL https://www.epa.gov/system/files/documents/2021-11/nams-work-plan_11_15_21_508-tagged.pdf (accessed 5.5.22).
EPA, 2021b. EPA Strategic Plan to Reduce the Use of Vertebrate Animals in Chemical Testing [WWW Document]. URL https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/strategic-plan-reduce-use-vertebrate-animals-chemical (accessed 5.5.22).
EPA, 2021c. Chlorothalonil: Revised Human Health Draft Risk Assessment for Registration Review [WWW Document]. URL https://www.regulations.gov/document/EPA-HQ-OPP-2011-0840-0080 (accessed 3.13.23).
EPA, 2020. Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Technical Chemicals & Supporting Retrospective Analysis [WWW Document]. URL https://www.regulations.gov/document/EPA-HQ-OPP-2016-0093-0181 (accessed 3.7.23).
EPA, 2018. Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program.
EPA, 2015. Use of an Alternate testing framework for classification of eye irritation [WWW Document]. URL https://www.epa.gov/sites/default/files/2015-05/documents/eye_policy2015update.pdf (accessed 11.13.23).
EURL ECVAM, 2021. EU Reference Laboratory for alternatives to animal testing (EURL ECVAM) [WWW Document]. URL https://joint-research-centre.ec.europa.eu/eu-reference-laboratory-alternatives-animal-testing-eurl-ecvam_en (accessed 11.3.22).
Farmahin, R., Manning, G.E., Crump, D., Wu, D., Mundy, L.J., Jones, S.P., Hahn, M.E., Karchner, S.I., Giesy, J.P., Bursian, S.J., Zwiernik, M.J., Fredricks, T.B., Kennedy, S.W., 2013. Amino Acid Sequence of the Ligand-Binding Domain of the Aryl Hydrocarbon Receptor 1 Predicts Sensitivity of Wild Birds to Effects of Dioxin-Like Compounds. Toxicological Sciences 131, 139–152. 10.1093/toxsci/kfs259 22923492
FDA, 2023. MOU 225–23-003 Memorandum of understanding between the National Institutes of Health (NCATS) and the Food and Drug Administration (FDA) for the Microphysiological Systems Program [WWW Document]. FDA. URL https://www.fda.gov/about-fda/domestic-mous/mou-225-23-003 (accessed 5.9.23).
FDA, 2021a. Advancing New Alternative Methodologies at FDA [WWW Document]. URL https://www.fda.gov/media/144891/download (accessed 7.19.23).
FDA, 2021b. S5(R3) Detection of Reproductive and Developmental Toxicity for Human Pharmaceuticals Guidance for Industry [WWW Document]. URL https://www.fda.gov/media/148475/download
FDA, 2020. Qualification Process for Drug Development Tools Guidance for Industry and FDA Staff [WWW Document]. URL https://www.fda.gov/media/133511/download (accessed 7.19.23).
FDA, 2018. Bioanalytical Method Validation Guidance for Industry [WWW Document]. URL https://www.fda.gov/regulatory-information/search-fda-guidance-documents/bioanalytical-method-validation-guidance-industry (accessed 7.31.23).
FDA, 2017a. FDA’s Predictive Toxicology Roadmap [WWW Document]. URL https://www.fda.gov/media/109634/download (accessed 5.5.22).
FDA, 2017b. Qualification of Medical Device Development Tools: Guidance for Industry, Tool Developers, and Food and Drug Administration Staff [WWW Document]. FDA. URL https://www.fda.gov/medical-devices/science-and-research-medical-devices/medical-device-development-tools-mddt (accessed 5.5.22).
Frick, A., Suzuki, O.T., Benton, C., Parks, B., Fedoriw, Y., Richards, K.L., Thomas, R.S., Wiltshire, T., 2015. Identifying genes that mediate anthracyline toxicity in immune cells. Front Pharmacol 6, 62. 10.3389/fphar.2015.00062 25926793
Friedman, K.P., Foster, M.J., Pham, L.L., Feshuk, M., Watford, S.M., Wambaugh, J.F., Judson, R.S., Setzer, R.W., Thomas, R.S., 2023. Reproducibility of organ-level effects in repeat dose animal studies. Comput Toxicol 28, 1–17. 10.1016/j.comtox.2023.100287 37990691
Harrill, A.H., 2020. ToxPoint: In the era of precision medicine, diversity should not be neglected in chemical safety assessment. Toxicol Sci 173, 3–4. 10.1093/toxsci/kfz232 31904857
Harrill, A.H., McAllister, K.A., 2017. New rodent population models may inform human health risk assessment and identification of genetic susceptibility to environmental exposures. Environ Health Perspect 125, 086002. 10.1289/EHP1274 28886592
Hartung, T., 2010. Evidence-based toxicology - the toolbox of validation for the 21st century? ALTEX 27, 253–263. 10.14573/altex.2010.4.253 21240468
Hoffmann, S., Kleinstreuer, N., Alépée, N., Allen, D., Api, A.M., Ashikaga, T., Clouet, E., Cluzel, M., Desprez, B., Gellatly, N., Goebel, C., Kern, P.S., Klaric, M., Kühnl, J., Lalko, J.F., Martinozzi-Teissier, S., Mewes, K., Miyazawa, M., Parakhia, R., van Vliet, E., Zang, Q., Petersohn, D., 2018. Non-animal methods to predict skin sensitization (I): the Cosmetics Europe database. Crit Rev Toxicol 48, 344–358. 10.1080/10408444.2018.1429385 29474128
Hoffmann, S., Saliner, A.G., Patlewicz, G., Eskes, C., Zuang, V., Worth, A.P., 2008. A feasibility study developing an integrated testing strategy assessing skin irritation potential of chemicals. Toxicol Lett 180, 9–20. 10.1016/j.toxlet.2008.05.004 18585875
ICCVAM, 2022. Symposium Webinar: Using New Approach Methodologies to Address Variability and Susceptibility Across Populations [WWW Document]. URL https://ntp.niehs.nih.gov/go/popvar (accessed 3.13.23).
ICCVAM, 2018. A Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products in the United States [WWW Document]. URL https://ntp.niehs.nih.gov/iccvam/docs/roadmap/iccvam_strategicroadmap_january2018_document_508.pdf (accessed 5.3.22).
ICCVAM, 2003. ICCVAM Guidelines for the Nomination and Submission of New, Revised, and Alternative Test Methods [WWW Document]. URL https://ntp.niehs.nih.gov/iccvam/suppdocs/subguidelines/sd_subg034508.pdf (accessed 5.3.22).
ICCVAM, 1997. Validation and Regulatory Acceptance of Toxicological Test Methods [WWW Document]. URL https://ntp.niehs.nih.gov/iccvam/docs/about_docs/validate.pdf (accessed 3.7.23).
ICH, 2013. ICH Harmonized Tripartite Guideline Photosafety Evaluation of Pharmaceuticals S10 [WWW Document]. URL https://database.ich.org/sites/default/files/S10_Guideline.pdf
Ishikawa, K., 1985. What is Total Quality Control? The Japanese Way. Translated by Lu, David J., 1st ed. Prentice-Hall.
Judson, R.S., Magpantay, F.M., Chickarmane, V., Haskell, C., Tania, N., Taylor, J., Xia, M., Huang, R., Rotroff, D.M., Filer, D.L., Houck, K.A., Martin, M.T., Sipes, N., Richard, A.M., Mansouri, K., Setzer, R.W., Knudsen, T.B., Crofton, K.M., Thomas, R.S., 2015. Integrated model of chemical perturbations of a biological pathway using 18 in vitro high-throughput screening assays for the estrogen receptor. Toxicol Sci 148, 137–154. 10.1093/toxsci/kfv168 26272952
Judson, R.S., Thomas, R.S., Baker, N., Simha, A., Howey, X.M., Marable, C., Kleinstreuer, N.C., Houck, K.A., 2019. Workflow for defining reference chemicals for assessing performance of in vitro assays. ALTEX 36, 261. 10.14573/altex.1809281 30570668
Karmaus, A.L., Mansouri, K., To, K.T., Blake, B., Fitzpatrick, J., Strickland, J., Patlewicz, G., Allen, D., Casey, W., Kleinstreuer, N., 2022. Evaluation of variability across rat acute oral systemic toxicity studies. Toxicological Sciences 188, 34–47. 10.1093/toxsci/kfac042 35426934
Kleinstreuer, N.C., Ceger, P., Watt, E.D., Martin, M., Houck, K., Browne, P., Thomas, R.S., Casey, W.M., Dix, D.J., Allen, D., Sakamuru, S., Xia, M., Huang, R., Judson, R., 2017. Development and validation of a computational model for androgen receptor activity. Chem. Res. Toxicol. 30, 946–964. 10.1021/acs.chemrestox.6b00347 27933809
Kleinstreuer, N.C., Hoffmann, S., Alépée, N., Allen, D., Ashikaga, T., Casey, W., Clouet, E., Cluzel, M., Desprez, B., Gellatly, N., Göbel, C., Kern, P.S., Klaric, M., Kühnl, J., Martinozzi-Teissier, S., Mewes, K., Miyazawa, M., Strickland, J., van Vliet, E., Zang, Q., Petersohn, D., 2018. Non-animal methods to predict skin sensitization (II): an assessment of defined approaches *. Crit Rev Toxicol 48, 359–374. 10.1080/10408444.2018.1429386 29474122
Kolle, S.N., Van Cott, A., van Ravenzwaay, B., Landsiedel, R., 2017. Lacking applicability of in vitro eye irritation methods to identify seriously eye irritating agrochemical formulations: Results of bovine cornea opacity and permeability assay, isolated chicken eye test and the EpiOcular; ET-50 method to classify according to UN GHS. Regulatory Toxicology and Pharmacology 85, 33–47. 10.1016/j.yrtph.2017.01.013 28163171
Krishna, S., Berridge, B., Kleinstreuer, N., 2021. High-throughput screening to identify chemical cardiotoxic potential. Chem Res Toxicol 34, 566–583. 10.1021/acs.chemrestox.0c00382 33346635
LaLone, C.A., Villeneuve, D.L., Lyons, D., Helgen, H.W., Robinson, S.L., Swintek, J.A., Saari, T.W., Ankley, G.T., 2016. Editor’s Highlight: Sequence Alignment to Predict Across Species Susceptibility (SeqAPASS): A Web-Based Tool for Addressing the Challenges of Cross-Species Extrapolation of Chemical Toxicity. Toxicol. Sci. 153, 228–245. 10.1093/toxsci/kfw119 27370413
Luechtefeld, T., Maertens, A., Russo, D.P., Rovida, C., Zhu, H., Hartung, T., 2016. Analysis of public oral toxicity data from REACH registrations 2008–2014. ALTEX 33, 111–122. 10.14573/altex.1510054 26863198
Madia, F., Pillo, G., Worth, A., Corvi, R., Prieto, P., 2021. Integration of data across toxicity endpoints for improved safety assessment of chemicals: the example of carcinogenicity assessment. Arch Toxicol 95, 1971–1993. 10.1007/s00204-021-03035-x 33830278
NIEHS, 2023a. Testing Regulations and Guidelines [WWW Document]. National Toxicology Program. URL https://ntp.niehs.nih.gov/go/837330 (accessed 7.19.23).
NIEHS, 2023b. Funding Opportunities for Test Method Developers [WWW Document]. Funding Opportunities for Test Method Developers. URL https://ntp.niehs.nih.gov/go/altfunding (accessed 5.9.23).
NIEHS, 2023c. International Cooperation on Alternative Test Methods [WWW Document]. International Cooperation on Alternative Test Methods. URL https://ntp.niehs.nih.gov/go/icatm (accessed 5.9.23).
NIEHS, 2023d. About ICCVAM [WWW Document]. About ICCVAM. URL https://ntp.niehs.nih.gov/go/iccvam (accessed 5.9.23).
OECD, 2023. No. 377: Initial Recommendations on Evaluation of Data from the Developmental Neurotoxicity (DNT) In-Vitro Testing Battery, OECD Series on Testing and Assessment. OECD Publishing, Paris.
OECD, 2022a. No. 364: Case study on the use of Integrated Approaches for Testing and Assessment for DNT to prioritize a class of Organophosphorus flame retardants, Series on Testing and Assessment. OECD Publishing, Paris.
OECD, 2022b. No. 367: Case Study on the use of an Integrated Approach for Testing and Assessment (IATA) for New Approach Methodology (NAM) for Refining Inhalation Risk Assessment from Point of Contact Toxicity of the Pesticide, Chlorothalonil, OECD Series on Testing and Assessment. OECD Publishing, Paris.
OECD, 2021a. Guideline No. 497: Defined Approaches on Skin Sensitisation, OECD Guidelines for the Testing of Chemicals, Section 4. OECD Publishing, Paris.
OECD, 2021b. No. 298: Guiding Principles on Good Practices for the Availability/Distribution of Protected Elements in OECD Test Guidelines, Series on Testing and Assessment. OECD Publishing.
OECD, 2018. No. 286: Guidance Document on Good In Vitro Method Practices (GIVIMP), OECD Series on Testing and Assessment. OECD Publishing. 10.1787/9789264304796-en
OECD, 2017. No. 255: Guidance Document on the Reporting of Defined Approaches to be Used Within Integrated Approaches to Testing and Assessment, OECD Series on Testing and Assessment. OECD Publishing, Paris. 10.1787/9789264274822-en
OECD, 2014. No. 203: New Guidance Document on an Integrated Approach on Testing and Assessment (IATA) for Skin Corrosion and Irritation, OECD Series on Testing and Assessment. OECD Publishing, Paris.
OECD, 2007. No. 69: Guidance Document on the Validation of (Quantitative) Structure-Activity Relationship [(Q)SAR] Models, OECD Series on Testing and Assessment. OECD Publishing, Paris. 10.1787/9789264085442-en.
OECD, 2005. No. 34: Guidance Document on the Validation and International Acceptance of New or Updated Test Methods for Hazard Assessment, OECD Environment, Health and Safety Publications Series on Testing and Assessment. OECD Publishing, Paris.
OECD, 1998. No. 1: OECD Principles of Good Laboratory Practice, Series on Principles of Good Laboratory Practice and Compliance Monitoring. OECD Publishing, Paris.
Pamies, D., Leist, M., Coecke, S., Bowe, G., Allen, D.G., Gstraunthaler, G., Bal-Price, A., Pistollato, F., Vries, R.B.M. de, Hogberg, H.T., Hartung, T., Stacey, G., 2022. Guidance document on Good Cell and Tissue Culture Practice 2.0 (GCCP 2.0). ALTEX Alternatives to animal experimentation 39, 30–70. 10.14573/altex.2111011 34882777
Parish, S.T., Aschner, M., Casey, W., Corvaro, M., Embry, M.R., Fitzpatrick, S., Kidd, D., Kleinstreuer, N.C., Lima, B.S., Settivari, R.S., Wolf, D.C., Yamazaki, D., Boobis, A., 2020. An evaluation framework for new approach methodologies (NAMs) for human health safety assessment. Regulatory Toxicology and Pharmacology 112, 104592. 10.1016/j.yrtph.2020.104592 32017962
Petersen, E., 2021. Characteristics to consider when selecting a positive control material for an in vitro assay. ALTEX. 10.14573/altex.2102111
Petersen, E.J., Ceger, P., Allen, D.G., Coyle, J., Derk, R., Garcia-Reyero, N., Gordon, J., Kleinstreuer, N.C., Matheson, J., McShan, D., Nelson, B.C., Patri, A.K., Rice, P., Rojanasakul, L., Sasidharan, A., Scarano, L., Chang, X., 2022a. U.S. federal agency interests and key considerations for new approach methodologies for nanomaterials. ALTEX - Alternatives to animal experimentation 39, 183–206. 10.14573/altex.2105041 34874455
Petersen, E.J., Elliott, J.T., Gordon, J., Kleinstreuer, N.C., Reinke, E., Roesslein, M., Toman, B., 2022b. Technical framework for enabling high-quality measurements in new approach methodologies (NAMs). ALTEX - Alternatives to animal experimentation. 10.14573/altex.2205081
Petersen, E.J., Uhl, R., Toman, B., Elliott, J.T., Strickland, J., Truax, J., Gordon, J., 2022c. Development of a 96-well electrophilic allergen screening assay for skin sensitization using a measurement science approach. Toxics 10, 257. 10.3390/toxics10050257 35622670
Pham, L.L., Watford, S., Pradeep, P., Martin, M.T., Thomas, R., Judson, R., Setzer, R.W., Paul Friedman, K., 2020. Variability in in vivo studies: Defining the upper limit of performance for predictions of systemic effect levels. Comput Toxicol 15, 1–100126. 10.1016/j.comtox.2020.100126 33426408
Piersma, A.H., van Benthem, J., Ezendam, J., Kienhuis, A.S., 2018. Validation redefined. Toxicol In Vitro 46, 163–165. 10.1016/j.tiv.2017.10.013 29024777
Prior, H., Casey, W., Kimber, I., Whelan, M., Sewell, F., 2019. Reflections on the progress towards non-animal methods for acute toxicity testing of chemicals. Regul Toxicol Pharmacol 102, 30–33. 10.1016/j.yrtph.2018.12.008 30578838
Rooney, J.P., Choksi, N.Y., Ceger, P., Daniel, A.B., Truax, J., Allen, D., Kleinstreuer, N., 2021. Analysis of variability in the rabbit skin irritation assay. Regulatory Toxicology and Pharmacology 122, 104920. 10.1016/j.yrtph.2021.104920 33757807
Rösslein, M., Elliott, J.T., Salit, M., Petersen, E.J., Hirsch, C., Krug, H.F., Wick, P., 2015. Use of Cause-and-Effect Analysis to Design a High-Quality Nanocytotoxicology Assay. Chem. Res. Toxicol. 28, 21–30. 10.1021/tx500327y 25473822
Rusyn, I., Chiu, W.A., Wright, F.A., 2022. Model systems and organisms for addressing inter-and intra-species variability in risk assessment. Regul Toxicol Pharmacol 132, 105197. 10.1016/j.yrtph.2022.105197 35636685
Sewell, F., Doe, J., Gellatly, N., Ragan, I., Burden, N., 2017. Steps towards the international regulatory acceptance of non-animal methodology in safety assessment. Regul Toxicol Pharmacol 89, 50–56. 10.1016/j.yrtph.2017.07.001 28689746
Shaffer, R.M., 2021. Environmental Health Risk Assessment in the Federal Government: A Visual Overview and a Renewed Call for Coordination. Environ. Sci. Technol. 55, 10923–10927. 10.1021/acs.est.1c01955 34310109
Slezák, P., Waczulíková, I., 2011. Letter to the Editor: Reproducibility and Repeatability. Physiol Res 60, 203–205.21469910
Smirnova, L., Hogberg, H.T., Leist, M., Hartung, T., 2014. Developmental neurotoxicity -challenges in the 21st century and in vitro opportunities. ALTEX 31, 129–156. 10.14573/altex.1403271 24687333
Strickland, J., Clippinger, A.J., Brown, J., Allen, D., Jacobs, A., Matheson, J., Lowit, A., Reinke, E.N., Johnson, M.S., Quinn, M.J., Mattie, D., Fitzpatrick, S.C., Ahir, S., Kleinstreuer, N., Casey, W., 2018. Status of acute systemic toxicity testing requirements and data uses by U.S. regulatory agencies. Regul Toxicol Pharmacol 94, 183–196. 10.1016/j.yrtph.2018.01.022 29408321
Strickland, J., Daniel, A.B., Allen, D., Aguila, C., Ahir, S., Bancos, S., Craig, E., Germolec, D., Ghosh, C., Hudson, N.L., Jacobs, A., Lehmann, D.M., Matheson, J., Reinke, E.N., Sadrieh, N., Vukmanovic, S., Kleinstreuer, N., 2019. Skin sensitization testing needs and data uses by US regulatory and research agencies. Arch Toxicol 93, 273–291. 10.1007/s00204-018-2341-6 30377734
Thomas, R.S., Bahadori, T., Buckley, T.J., Cowden, J., Deisenroth, C., Dionisio, K.L., Frithsen, J.B., Grulke, C.M., Gwinn, M.R., Harrill, J.A., Higuchi, M., Houck, K.A., Hughes, M.F., Hunter, E.S., Isaacs, K.K., Judson, R.S., Knudsen, T.B., Lambert, J.C., Linnenbrink, M., Martin, T.M., Newton, S.R., Padilla, S., Patlewicz, G., Paul-Friedman, K., Phillips, K.A., Richard, A.M., Sams, R., Shafer, T.J., Setzer, R.W., Shah, I., Simmons, J.E., Simmons, S.O., Singh, A., Sobus, J.R., Strynar, M., Swank, A., Tornero-Valez, R., Ulrich, E.M., Villeneuve, D.L., Wambaugh, J.F., Wetmore, B.A., Williams, A.J., 2019. The next generation blueprint of computational toxicology at the U.S. Environmental Protection Agency. Toxicol Sci 169, 317–332. 10.1093/toxsci/kfz058 30835285
Tox21, n.d. Tox21 - Toxicology in the 21st Century [WWW Document]. Tox21. URL https://tox21.gov/ (accessed 5.9.23).
Tsuji, R., Crofton, K.M., 2012. Developmental neurotoxicity guideline study: issues with methodology, evaluation and regulation. Congenit Anom (Kyoto) 52, 122–128. 10.1111/j.1741-4520.2012.00374.x 22925212
van der Zalm, A.J., Barroso, J., Browne, P., Casey, W., Gordon, J., Henry, T.R., Kleinstreuer, N.C., Lowit, A.B., Perron, M., Clippinger, A.J., 2022. A framework for establishing scientific confidence in new approach methodologies. Arch Toxicol 96, 2865–2879. 10.1007/s00204-022-03365-4 35987941
Wikoff, D., Lewis, R.J., Erraguntla, N., Franzen, A., Foreman, J., 2020. Facilitation of risk assessment with evidence-based methods – A framework for use of systematic mapping and systematic reviews in determining hazard, developing toxicity values, and characterizing uncertainty. Regulatory Toxicology and Pharmacology 118, 104790. 10.1016/j.yrtph.2020.104790 33038430
Wilkinson, M.D., Dumontier, M., Aalbersberg, Ij.J., Appleton, G., Axton, M., Baak, A., Blomberg, N., Boiten, J.-W., da Silva Santos, L.B., Bourne, P.E., Bouwman, J., Brookes, A.J., Clark, T., Crosas, M., Dillo, I., Dumon, O., Edmunds, S., Evelo, C.T., Finkers, R., Gonzalez-Beltran, A., Gray, A.J.G., Groth, P., Goble, C., Grethe, J.S., Heringa, J., ’t Hoen, P.A.C., Hooft, R., Kuhn, T., Kok, R., Kok, J., Lusher, S.J., Martone, M.E., Mons, A., Packer, A.L., Persson, B., Rocca-Serra, P., Roos, M., van Schaik, R., Sansone, S.-A., Schultes, E., Sengstag, T., Slater, T., Strawn, G., Swertz, M.A., Thompson, M., van der Lei, J., van Mulligen, E., Velterop, J., Waagmeester, A., Wittenburg, P., Wolstencroft, K., Zhao, J., Mons, B., 2016. The FAIR Guiding Principles for scientific data management and stewardship. Sci Data 3, 160018. 10.1038/sdata.2016.18 26978244
Wolffe, T.A.M., Whaley, P., Halsall, C., Rooney, A.A., Walker, V.R., 2019. Systematic evidence maps as a novel tool to support evidence-based decision-making in chemicals policy and risk management. Environ Int 130, 104871. 10.1016/j.envint.2019.05.065 31254867
Zhang, J.H., Chung, T.D., Oldenburg, K.R., 1999. A simple statistical parameter for use in evaluation and validation of high throughput screening assays. J Biomol Screen 4, 67–73. 10.1177/108705719900400206 10838414
Zhang, X.D., 2011. Illustration of SSMD, z score, SSMD*, z* score, and t statistic for hit selection in RNAi high-throughput screens. J Biomol Screen 16, 775–785. 10.1177/1087057111405851 21515799