# Executive Summary

New approach methodologies (NAMs) are being developed with increasing frequency and are being utilized to provide regulatory and non-regulatory assessments of the potential toxic effects of chemicals and products on human health and the environment. These NAMs are being used to investigate the biological mechanisms underlying toxicological processes, to assist in the evaluation of new and existing products, and to generate hazard identification and dose-response relationship information for health and environmental hazard classification and risk assessment purposes. This report was developed by ICCVAM to help developers and end users build confidence in NAMs. This confidence can be achieved through the implementation of flexible, fit-for-purpose validation strategies that consider the intended application of the NAM. This report helps to build confidence by describing concepts such as context of use, biological relevance, and technical characterization of NAMs. The report looks at U.S. federal agency regulatory acceptance of NAMs and the potential for international harmonization, and reviews best practices for quality tools and technical assessment of NAMs. The report also emphasizes the need for communication between the developers, end users, and regulatory agencies. The outdated one-size-fits-all strategy for validation does not work in an advanced field like NAMs. ICCVAM is an organization that can support this transition to more modern approaches in an advisory capacity, via coordination of validation efforts, and by establishing opportunities for research collaboration. Therefore, ICCVAM has developed this report, in cooperation with 17 federal regulatory agencies and research laboratories, to help developers, end users, and regulatory agencies build confidence in NAMs so they can be implemented to supplement or replace animal testing for regulatory and non-regulatory purposes.