# Disclaimer

This report has been developed as a resource for U.S. federal agencies and stakeholders seeking to establish confidence in new approaches that replace, reduce, or refine the use of animals in testing. The principles described in this report were developed with input from staff from 17 federal agencies, multiple interagency workgroups, the public, and the Scientific Advisory Committee on Alternative Toxicological Methods. As such, this report does not necessarily reflect the opinions or policy of any agency or workgroup. It does not create rights for any person or party and should not be taken as a commitment by any federal agency. This report does not establish any legally enforceable responsibilities. Instead, this report describes the Interagency Coordinating Committee on the Validation of Alternative Methods’ (ICCVAM) current thinking on a topic and should be viewed only as recommendations, unless specific regulatory or statutory requirements are cited. The use of the word “should” means that something is suggested or recommended, but not required.