# ICCVAM Agency Representatives

ICCVAM committee membership at the time of publication of this report

*Principal agency representative; +Alternate principal agency representative

## Agency for Toxic Substances and Disease Registry

- * Moiz Mumtaz, PhD
  Patricia Ruiz, PhD

## U.S. Consumer Product Safety Commission

- * John Gordon, PhD
  + Kristina Hatlelid, PhD, MPH
  + Eric Hooker, MS
  + Joanna Matheson, PhD

## U.S. Department of Agriculture

- * Jessie Carder
  + Patrice Klein, MS, VMD, DACPV, DACVPM
  Erika Edwards
  Ben Green, PhD
  Katherine Horak, PhD

## U.S. Department of Defense

- * Shannon Marko, DVM, DACLAM
  + Natalia Garcia-Reyero Vinas, PhD (Co-Chair)
  + Saber Hussain, PhD, ATS Fellow, AFRL Fellow
  + Elaine Merrill, PhD
  Matthew Grogg, PhD
  Donald Cronce, PhD

## U.S. Department of Energy

- R. Todd Anderson, PhD

## U.S. Department of the Interior

- * Barnett A. Rattner, PhD
  + Jessica K. Leet, PhD

## U.S. Department of Transportation

- * Steve Hwang, PhD
  + Rebecca Rothhaas
  + Ryan Vierling, PhD

## U.S. Department of Veterans Affairs Office of Research and Development

- * Holly Krull, PhD
  + George Lathrop, Jr., DVM, MS, DACLAM

## U.S. Environmental Protection Agency

- Office of Chemical Safety and Pollution Prevention
  - Charles Kovatch
- Office of Pesticide Programs
  - Monique Perron, PhD
    William (Bill) Eckel, PhD
    Cecilia Tan, PhD
- Office of Pollution Prevention and Toxics
  - * Anna Lowit, PhD
    Louis (Gino) Scarano, PhD
- Office of Research and Development
  - + Alison Harrill, PhD
    Kelly Carstens, PhD
    Grace Patlewicz, PhD

## Food and Drug Administration

- Center for Biologics Evaluation and Research
  - Leslie Wagner
    Allen Wensky, PhD
- Center for Devices and Radiological Health
  - + Jennifer Goode, BS
    Simona Bancos, PhD
    Rakhi M. Dalal-Panguluri, PhD
- Center for Drug Evaluation and Research
  - Paul C. Brown, PhD
    Nakissa Sadrieh, PhD
- Center for Food Safety and Applied Nutrition
  - * Suzanne Fitzpatrick, PhD (Co-Chair)
    Omari J. Bandele, PhD
    Patrick Crittenden, PhD
    Shruti Kabadi, PhD
- Center for Tobacco Products
  - Jueichuan (Connie) Kang, PhD
- Center for Veterinary Medicine
  - M. Cecilia Aguila, DVM
    Li You, PhD
- National Center for Toxicological Research
  - Mugimane (Manju) Manjanatha, PhD
- Office of the Chief Scientist
  - Tracy Chen, PhD
    Chad P. Nelson, PhD, MSPH

## National Cancer Institute

- * Brian Cholewa, PhD
  + Ron Johnson, PhD
  Gary Robinson, PhD

## National Institute for Occupational Safety and Health

- * Stephen Leonard, PhD

## National Institute for Environmental Health Sciences

- * Warren Casey, PhD
  + Stephen Ferguson, PhD
  + David M. Reif, PhD
  Nicole Kleinstreuer, PhD

## National Institute of Standards and Technology

- * John Elliott, PhD
  + Elijah Petersen, PhD

## National Institutes of Health

- * Nicolette Petervary, VMD, MS, DACAW
  Michael Eichner, DVM, DACLAM

## National Library of Medicine

- * Dina N. Paltoo, PhD, MPH, CPI

## Occupational Safety and Health Administration

- * Deana Holmes, MT
  + Janet Carter, MS