# ICCVAM Validation Workgroup

## Agency for Toxic Substances and Disease Registry

- Moiz Mumtaz, PhD

## Consumer Product Safety Commission

- John Gordon, PhD (Co-Chair)

## Department of Defense

- Donald Cronce, PhD
  Natalia Garcia-Reyero Vinas, PhD
  Matthew Johnson, DVM, DACLAM (to June 2022)
  Emily N. Reinke, PhD (to April 2022)

## Department of Veterans Affairs

- George Lathrop, Jr., DVM, MS, DACLAM

## Environmental Protection Agency

- Office of Pesticide Programs
  - Anna Lowit, PhD
    Scott Lynn, PhD
    Monique Perron, ScD
- Office of Research and Development
  - Kelly Carstens, PhD
    Alison Harrill, PhD
    Nisha Sipes, PhD

## Food and Drug Administration

- Center for Devices and Radiological Health
  - Jennifer Goode, BS
- Center for Drug Evaluation and Research
  - Paul C. Brown, PhD
- Center for Food Safety and Applied Nutrition
  - Suzanne Fitzpatrick, PhD (Co-Chair)
    Anneliese Striz, PhD
- Center for Tobacco Products
  - Jueichuan (Connie) Kang, PhD
- Office of the Chief Scientist
  - Tracy Chen, PhD

## National Institute of Environmental Health Sciences

- Warren Casey, PhD

- National Toxicology Program Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM)
  - Helena Hogberg, PhD
    Nicole Kleinstreuer, PhD

## National Institutes of Health

- National Center for Advancing Translational Sciences
  - Menghang Xia, PhD

## National Institute of Standards and Technology

- Elijah Petersen, PhD (Co-Chair)

## Occupational Safety and Health Administration

- Janet Carter, MS

## NICEATM Support Contract Staff (Inotiv)

- David Allen, PhD (to December 2023)
  Michaela Blaylock
  Amber Daniel, MTox
  Agnes Karmaus, PhD (to April 2023)