# 7.0 Conclusion and Implementation

This report is intended to assist method developers, regulated industry stakeholders, and federal agencies in the development, validation, qualification, and acceptance of scientifically relevant NAMs. Here, we have described key concepts that should be considered to allow for efficient and timely development of NAMs that are fit-for-purpose, reliable, and provide information relevant to the species of interest. All the information may or may not apply to any specific method, DA, or IATA. There may also be other concepts that apply to a method, DA, or IATA that are not discussed in this report. It is important for developers to work closely with federal agencies and end users with an eye toward the intended use of the NAM, particularly for risk assessment applications in a regulatory review. Establishing scientific confidence in NAMs and validating or qualifying methods for specific purposes and COUs should be iterative processes that evolve via multi-directional communication among stakeholders.

The field of NAMs is an evolving one, and new considerations on NAM validation and qualification may emerge that were not anticipated at the time of the writing of this report. Consequently, stakeholders engaged in NAM development, validation and qualification may need to remain flexible and open to incorporating considerations not described here. This report will be updated on a regular basis and as needed.