# 6.0 Communication and Training to Encourage Use of NAMs

Communication from agencies about the acceptability of specific NAMs and training on NAMs can facilitate their use. Where appropriate and feasible, agencies could communicate publicly when and how a NAM is acceptable, depending on agency-specific rules and policies. For example, NAMs may be described in GDs or on publicly available web sites. Regulatory agencies can use existing training programs or implement new programs for staff and provide publicly available training, when possible, for new methods. Building confidence in new approaches can begin even before a NAM is validated or qualified through education of the scientific community. These early education efforts can focus on the basic science of the new approaches. As approaches mature and data supporting the validity of an approach accumulates, the educational efforts can shift to familiarizing the community with these data. Training on specific use and interpretation of NAMs can occur when the NAMs have been evaluated for particular COUs. Entities such as OECD, ICCVAM, and other validation organizations and scientific societies can also provide training and access to information about NAMs that will support confidence in their use.

Interaction between NAM developers, industry users and the regulators can facilitate the development and adoption of methods. Such interactions can occur through participation of all parties in scientific meetings where such methods are discussed and through more formal regulatory interactions according to agency-specific processes. As noted above, development of appropriate COUs and qualification data sets can be an iterative process. COUs and applicability domains can shift during the development and exploration of a NAM as data accumulate. Continued communication between all parties during this process can help assure that an appropriate path to acceptance of a NAM is taken.

Even if a NAM is available for an endpoint and is accepted by a regulatory agency, the sponsor of an application may choose to use other approaches such as a traditional animal test, and thus the NAM may not always be submitted in a regulatory application. There might be several reasons for this that are beyond the control of regulatory authorities. Although a regulatory agency can suggest or recommend substituting a NAM or several NAMs for a traditional test, the sponsor of a compound may not always be obligated to follow the suggestion. Education and familiarity with NAMs among all stakeholders are necessary to build sufficient confidence for NAM adoption.