# 5.0 U.S. and International Harmonization

Coordination among U.S. federal agencies and more broadly with international regulatory authorities will help ensure harmonization of approaches to validate NAMs and support their application and implementation. ICCVAM and NICEATM play important roles in facilitating communication and collaboration, both domestically and globally.

## 5.1 U.S. Harmonization: Role of ICCVAM and NICEATM

The ICCVAM Authorization Act outlines the following purposes of ICCVAM (42 U.S.C 285l-3, 2000; NIEHS, 2023d):

- Increase the efficiency and effectiveness of U.S. federal agency test method review.
- Eliminate unnecessary duplication of effort and share experience among U.S. federal regulatory agencies.
  ○ This is accomplished via several means, such as monthly meetings, workgroups, open public meetings (Public Forum) and scientific advisory groups (Scientific Advisory Committee on Alternative Toxicological Methods).
- Optimize utilization of scientific expertise outside the U.S. Federal Government.
  ○ This is often accomplished by setting up meetings and workshops with ICATM partners as well as with numerous scientists at conferences.
- Ensure that new and revised test methods are validated to meet the needs of U.S. federal agencies.
  ○ Federal agency scientists and regulators cooperate with developers to ensure that the methods being produced will address a regulatory need.
- Reduce, refine, or replace the use of animals in testing where feasible.

ICCVAM facilitates interagency and international collaborations promoting the development, regulatory acceptance or qualification, and use of alternative tests that encourage the reduction, refinement, or replacement of animal test methods. ICCVAM provides guidance to test method developers, evaluates recommendations from expert peer reviews of alternative toxicological test methods, and makes recommendations on the use of reviewed test methods to appropriate federal agencies. ICCVAM achieves its functions through ad hoc technical workgroups, managed by NICEATM, to perform specific tasks important for the development or validation of alternatives to animal testing. One such ongoing example is ICCVAM’s support in coordinating an interlaboratory prevalidation study for a NAM developed by EPA based on an in vitro human thyroid microtissue assay for chemical screening (Deisenroth et al., 2020).

NICEATM, an office within the National Institute of Environmental Health Sciences (NIEHS) Division of Translational Toxicology, provides technical, scientific, and operational support for ICCVAM and ICCVAM workgroup activities, peer review panels, expert panels, workshops, and validation efforts. In addition to supporting ICCVAM, NICEATM:

- Conducts test method analyses and evaluations and coordinates independent validation studies on novel and high-priority alternative testing approaches.
- Provides information to test method developers, regulators, and regulated industry through the NICEATM website, the Integrated Chemical Environment, and workshops on topics of interest.
- Supports activities of the NIEHS Division of Translational Toxicology, especially those contributing to the U.S. government’s interagency Toxicology in the 21st Century (Tox21) consortium.

The forum for interagency communication provided by ICCVAM and the support provided by NICEATM serve to ensure that limited resources are being leveraged effectively to coordinate U.S. federal agency efforts to validate and qualify NAMs for regulatory application.

## 5.2 U.S. Harmonization: Additional Federal Collaborations to Advance 3Rs

U.S. federal agencies collaborate on NAMs in many ways in addition to their participation in ICCVAM. For example, Tox21 (Tox21, n.d.) is a federal collaboration among EPA, the NIEHS Division of Translational Toxicology, the National Center for Advancing Translational Sciences (NCATS) within the National Institutes of Health, and FDA. The goal of Tox21 is to develop better toxicity assessment methods to efficiently test whether certain chemical compounds may have the potential to disrupt biological processes in the human body and lead to negative health effects. Tox21 has produced a number of seminal publications and analyses that have been put into regulatory use, for example in the EPA’s Endocrine Disruptor Screening Program (EPA, 2023). NICEATM and EPA have also worked closely on multiple studies to reduce or replace the use of animals in regulatory testing. This includes retrospective analyses to eliminate the use of animals for: 1) dermal acute toxicity to pesticides and pesticide formulations (EPA, 2020); 2) determining if using in vitro data alone will suffice for dermal absorption factor derivation for human health risk assessment of pesticides (Allen et al., 2021); and 3) determining if the same level of protection of non-target aquatic vertebrates can be achieved with in vivo acute toxicity testing on fewer than three fish species (Ceger et al., 2023). FDA also collaborates with NCATS to further develop microphysiological system technologies to promote their advancement and accelerate translational use (FDA, 2023).

## 5.3 International Harmonization

In addition to the international collaborative efforts facilitated through ICCVAM, U.S. agencies independently collaborate internationally to advance the acceptance of NAMs. Examples include ICATM, U.S. engagement with the United Nations subcommittee of experts on the Globally Harmonized System for Classification and Labelling of Chemicals (GHS), engagement with ICH to develop guidances describing the use of NAMs, and participation in the OECD Test Guidelines Programme and Working Party on Hazard Assessment.

ICATM was established as a partnership among validation organizations from the U.S. (ICCVAM), Japan (JaCVAM), European Union (EURL ECVAM), and Canada (Environmental Health Science and Research Bureau within Health Canada). Other participating organizations include the Korean Center for the Validation of Alternative Methods, the Brazilian Center for the Validation of Alternative Methods, and the Chinese Food and Drug Administration and Guangdong Center for Disease Control and Prevention. The overarching goals of this group have been:

- To establish international cooperation in the critical areas of validation studies, independent peer review, and development of harmonized recommendations to ensure that alternative methods/strategies are more readily accepted worldwide.
- To establish international cooperation necessary to ensure that new alternative test methods/strategies adopted for regulatory use will provide equivalent or improved protection for people, animals, and the environment, while replacing, reducing or refining (causing less pain and distress) animal use whenever scientifically feasible.

Within the United Nations, the GHS subcommittee has established a workgroup to update various chapters of the GHS to establish specific criteria for use of NAMs in various hazard classes (e.g., skin irritation/corrosion, eye irritation/serious eye damage, skin sensitization). These efforts have been fruitful in advancing NAMs on an international level and have established DAs as acceptable methods for hazard determinations. These international efforts are important not only in advancing NAMs but also providing expertise to international regions that may not have sufficient resources in this area.

The value of harmonizing approaches to the use of NAMs is also illustrated in the activities of the ICH. Several guidances developed by ICH describe the use of alternative methods that are considered acceptable approaches by multiple regulatory authorities and industry groups around the world. These methods were assessed by expert working groups within the ICH process and incorporated into the guidances as appropriate. Examples include the use of in chemico and in vitro methods for the assessment of phototoxicity (ICH, 2013). In addition, the ICH guidance on reproductive and developmental toxicity includes some contexts of use for alternative assays as well as recommendations on the approach to qualify such assays and a list of biological endpoint reference compounds (FDA, 2021b).

The OECD is an international forum for harmonizing regulatory test guidelines and guidance documents and is increasingly focused on validation and use of NAMs. ICCVAM plays an important role in coordinating and contributing to the U.S. position for the OECD Health Effects Test Guidelines Programme. The U.S. National Coordinator represents the United States at the annual meeting of the Working Group of National Coordinators and in other test guideline development activities. In that role, the U.S. National Coordinator solicits input from relevant ICCVAM agencies for OECD TG activities that involve any aspect of the 3Rs. Subject matter experts from ICCVAM agencies serve on multiple OECD expert groups to provide scientific guidance on the development of OECD products such as test guidelines, DAs, and guidance documents. OECD test guidelines are used by stakeholders of the 38 OECD member countries to assess chemical safety. The OECD Mutual Acceptance of Data clause ensures that safety data generated using an OECD test guideline will be accepted by all the member countries, avoiding redundant testing. ICCVAM agencies also contribute to the OECD IATA Case Studies Project, which allows countries to share and collaborate on the use of novel methodologies in IATA for evaluating chemical safety within a regulatory context.