# 4.0 U.S. Federal Agency Acceptance of NAMs

## 4.1 Understanding Regulatory Needs and Decision Contexts

Federal agencies have different authorities to request, obtain, and use toxicology data. These differ according to statute, regulations, and product category. A NAM may be useful and adequate in some statutory or regulatory contexts but not in others. Consequently, developers and users of a NAM must consider the context in which it will be used. Some potential contexts would include but are not limited to DAs, IATAs, or standalone methods.

Whether a NAM will be acceptable for a regulatory or other purpose depends on the nature of the decision to be made, the adequacy of the NAM for its intended use, and the extent to which the regulatory submission depends on the NAM results to support safety, efficacy, and/or risk determination(s). A NAM with high sensitivity and low specificity that identifies a signal of concern may be useful for applications in which a large number of compounds will be screened to prioritize further assessments. Such a NAM may be of limited utility when deciding what dose of a single compound is safe for exposure. In some cases, agencies might look for signals of concern in data-poor situations (hazard identification). In other cases, agencies may need to make more quantitative decisions about compounds (risk assessment) and may be unwilling to accept a high level of uncertainty in outputs from NAMs that are used to inform those decisions. The implementation of performance characteristics should reflect how the NAM will be used and be individualized to each NAM and its COU.

To facilitate this process some agencies may want to evaluate NAMs prior to their use in a regulatory decision-making process. The evaluation will likely focus on the NAM having a well-defined COU. One of the purposes of the evaluation is to enable regulators to apply the results generated using the NAM without needing to re-review all of the underlying supporting data for the NAM (see documents cited in Table 1).

## 4.2 Context of Use Considerations

The purpose of the NAM should be clearly communicated (e.g., hazard identification, potency evaluation, point of departure for quantitative risk assessment etc.), and the NAM should be assessed based on that purpose. It is appropriate to focus application of a newly developed NAM on a single COU. However, additional COUs can be added at later times with appropriate supporting data. A COU generally needs to be focused on a particular regulatory need. Initial efforts at qualifying a NAM may be most successful if the COU is narrow. A COU could be expanded with additional data as appropriate. Regulatory needs differ across agencies so a COU for a particular NAM might also differ. Establishing an appropriate COU for a proposed NAM prior to conducting a full qualification effort is essential.

Determination of an appropriate COU should generally be discussed between the NAM developer and the agency(ies) for which the COU is relevant. Several iterations of a COU may be necessary before an acceptable one is defined. A COU may even change during collection of data as the applicability and limitations of a NAM are further defined.

## 4.3 Evolution of Confidence Based on Experience Gained

Incorporation of a NAM into regulatory use requires sufficient confidence in the method by regulators and the regulated industry. Validation and qualification support this confidence but may not be sufficient to ensure implementation. Education about and experience with a NAM are generally necessary before a NAM will meet widespread acceptance for its purpose. Cost, complexity, availability of reagents and staff trained in the conduct and interpretation of a NAM are some factors that can limit the adoption of a NAM even if validation and qualification data are available.

The performance of a NAM intended to supplement or replace an existing approach will generally need to be compared to the existing approach. There is often high confidence in existing approaches with which there is substantial experience. These existing approaches may not have undergone formal validation but repeated successful use of the existing approach along with assumed inherent validity of testing in animals often builds substantial confidence in the approach. Users need to know that a NAM will be as good or better than existing approaches when using the results to make decisions about safety. Varying levels of uncertainty may be acceptable for different COUs, with increasing confidence needed as one progresses through prioritization and screening to hazard characterization to risk assessment, for example.

One mechanism to build confidence in a NAM is for users to provide data from a NAM in parallel with data from the existing method that the NAM is intended to replace or supplement. Voluntary sharing of information on NAMs within and across industries can help establish a sufficiently large body of data to support confidence in the methods. In time, agencies and industry may see how the NAM can fit into the existing assessment paradigms without compromising safety standards.