# 3.0 Applying the Key Concepts to Build Confidence in NAMs

Validation should be a robust yet flexible process wherein scientific confidence is established by determining the fitness of a NAM for a specific COU. Where possible and appropriate, there should be evidence to support that the use of an alternative method will provide information that is as good as or better than the existing method, and that it will lead a regulatory review to decisions that are as protective for human health. The COU determines the detailed criteria and implementation of the key concepts. In order to determine whether NAMs are fit for a particular purpose, both the COU and the relevant biology the NAM is intended to cover should be clearly defined. The NAM must be well-described and provide technically reliable information that is biologically relevant and/or health-protective for the endpoint or process of concern. The composition of the information provided by the NAM must be sufficiently transparent to allow for independent review to ensure integrity and trustworthiness. Where appropriate and possible, building confidence in NAMs may include demonstrating that the NAM provides information of equivalent or better quality and relevance to the species of interest for regulatory decision-making as compared, either quantitatively or qualitatively, to the information provided by the traditional animal test method. To avoid being constrained by the status quo, the possibility that the NAM may provide better quality and more relevant information for regulatory decision-making than the traditional animal test method must be acknowledged. This requires a validation framework that allows for this possibility and accounts for circumstances in which a comparison to data from traditional animal test methods may not be possible.

## 3.1 Context of Use

Establishing COU, or the intended utilization of a NAM, includes crafting a statement that fully and clearly describes the way the NAM is intended to be used and its regulatory purpose (if applicable). U.S. federal agencies operate under statutes and regulations particular to each agency (see, e.g., Shaffer, 2021), and therefore have different criteria for a NAM to be acceptable and applicable toward each agency’s individual requirements. In some cases, even within an agency (e.g., different centers of the U.S. Food and Drug Administration [FDA], offices of the U.S. Environmental Protection Agency [EPA]) there may be different needs depending on the area of regulation. This is further complicated internationally where regulations in other countries may differ from U.S. regulations such that methods acceptable in one country for a particular COU may not be acceptable elsewhere. Consequently, even though a NAM may be validated to address a specific endpoint for one (or multiple) COU under a particular guidance/regulation, it may not be considered acceptable under a different guidance/regulation among various agencies, regulatory jurisdictions, and countries. To better understand this diverse regulatory landscape, ICCVAM has collected information from a variety of agencies, both domestically and internationally, to characterize agency needs specific to particular toxicity endpoints (NIEHS, 2023a; examples shown in Table 2).

Table 2 Manuscripts Produced by ICCVAM Workgroups that Provide Details about Agency Testing Needs for Selected Topics

Testing need focus | Reference
Acute toxicity testing | Strickland et al., 2018
Ecotoxicity testing | Ceger et al., 2022
In vitro to in vivo extrapolation | Chang et al., 2022
Nanomaterials testing using NAMs | Petersen et al., 2022a
Skin sensitization | Daniel et al., 2018; Strickland et al., 2019
Skin and eye irritation testing | Choksi et al., 2019

NAMs with different COUs such as screening/prioritization and hazard identification can be different from those that are designed to answer specific questions regarding toxicological mechanisms and/or support quantitative risk assessments, and as such, different criteria may be developed and applied to evaluating and validating NAMs for each purpose. Many new methods are developed in academic settings to address basic research questions that may be specific or exploratory in nature. Occasionally, it is recognized that one of these methods might have the potential to serve a role other than basic research into more applied areas, such as regulatory decision-making. It is important for developers of new methods to meet with both federal agencies and/or intended users or stakeholders prior to validating a NAM to ensure that validation studies designed to establish confidence will be tailored appropriately to the intended COU.

Other NAMs may be more useful for product discovery and development. A NAM may be adopted for screening new molecules for desirable (e.g., pharmacologic) or potentially undesirable (toxic) activities. These data may be used to make decisions about what molecules should be taken into further development. Standardization of testing methods can support innovation by focusing effort and resources on new technological or therapeutic discoveries, rather than method development or testing. These uses of NAMs tend to be outside the regulatory authority of most federal agencies. However, it is still recommended that the key concepts to establish scientific confidence in NAMs are applied to ensure that high-quality data are being obtained. It is recognized that these uses of NAMs can both support the 3Rs directly and provide preliminary data and experience that can support further development of a NAM, potentially enabling its use for a regulatory purpose.

## 3.2 Biological Relevance

The relevance of a NAM describes the relationship between the test and the effect in the target species and whether the test method is meaningful and useful for a defined purpose, with the limitations identified. Adequate demonstration of the relevance of a NAM is an important contributor to confidence in a NAM. Biological relevance can be demonstrated in various ways depending on the available information, as detailed below.

Considerations surrounding biological relevance detailed in the following subsections include:

- What type of information does the NAM provide? Is there an understanding of the biology and mechanisms leading to the outcome/endpoint?
- What reference data are available for benchmarking the outcome that the NAM is intended to query?
- What are the considerations on whether, and how, to benchmark outputs of a NAM to an established laboratory method?

Additional considerations surrounding biological relevance may also be important depending on the specific circumstances of the validation application.

### 3.2.1 Mechanistic Understanding

Consideration of the biology of the species of interest (generally human, but often other species) is important when assessing the relevance of a NAM. Comparisons of the information provided by the NAM to in vivo biology should be supported, where possible, by existing mechanistic knowledge (e.g., an adverse outcome pathway [AOP] or toxicologically relevant biological process). Anchoring a NAM to an established AOP via a molecular initiating event or one or more key events can help demonstrate the biological relevance of the NAM. On the other hand, lack of an established AOP for the outcome being predicted by a NAM does not necessarily exclude the NAM from being potentially useful, and such supporting information may come from mechanistic insights provided by in vivo data and understanding of the biology of the target species. It is important for a NAM to be comprehensively characterized and clearly describe what biological event is being measured and how it relates to the adverse outcome or hazard of concern.

A description of the NAM should address biological plausibility of the model for predicting in vivo outcomes and/or provide a mechanistic linkage to a biological process, mechanism, or AOP. For example, if a NAM is to predict the possibility of a human pharmaceutical to induce fetal malformations or embryo-fetal lethality, there should be an understanding of the mechanisms of embryo-fetal development (e.g., cell migration, differentiation, vasculogenesis, neurulation, gastrulation) and the connection to subsequent developmental adverse effects studied with the model (FDA, 2021b). While the relationship to the in vivo effect being predicted may be correlative in nature, it is more challenging to build confidence in NAM predictions from only correlative or empirical relationships; therefore, tests with clear biologic relevance to the process being evaluated are preferred. The absence of an understanding of the biological and mechanistic relevance of a NAM may limit its applicability to boundaries tightly defined by the data used to validate the NAM and make it difficult to extend NAMs to chemical classes outside those used in establishing and validating the NAM.

An AOP is a useful organizing framework to link molecular and cellular perturbations with adverse health outcomes and can be used to develop and anchor NAMs that represent important toxicological processes. Examples exist for endpoints that do have well-established AOPs, such as skin sensitization (Kleinstreuer et al., 2018). For endpoints lacking well-established AOPs, the mechanistic relevance of the NAM can instead be considered based on factors such as biological pathways or processes (Table 3).

Table 3 Examples of Endpoints Where Biological and Mechanistic Relevance of NAMs has Been Demonstrated^*^

Endpoint | Summary | References
Skin sensitization | The endpoint has a well-developed human relevant AOP to which defined approaches combining several NAMs are mapped and described in OECD Guideline 497. | Kleinstreuer et al., 2018; OECD, 2021a
Endocrine disruption | Established pathway models using complementary NAMs as part of an integrated strategy are available for estrogen and androgen receptor activity. EPA accepts these NAMs for Tier 1 screening in the Endocrine Disruptor Screening Program. | Judson et al., 2015; Kleinstreuer et al., 2017; EPA, 2023
Developmental neurotoxicity | Limited AOPs exist for this complex endpoint. Instead, a battery of NAMs covering critical processes of human neurodevelopment has been developed. An OECD GD on the battery is available that includes Integrated Approaches to Testing and Assessment (IATA) case studies. | Crofton and Mundy, 2021; OECD, 2022a; OECD, 2023
Inhalation toxicity | An alternative approach using an in vitro human cell-based assay and computational modeling was used to derive a point of departure for use in EPA human health risk assessment. This approach was also published as an OECD IATA case study. | Corley et al., 2021; EPA, 2021c; OECD, 2022b
Eye irritation | A guidance document describing an alternate testing framework for assessing eye irritation potential of pesticides and pesticide products. Available in vivo, in vitro, and ex vivo test methods were reviewed with respect to their relevance to human ocular anatomy and mechanisms of toxicity. | EPA, 2015; Clippinger et al., 2021
Skin irritation | A guidance document proposing an IATA for skin corrosion and irritation using existing information, physicochemical properties, and other non-testing methods. | OECD, 2014

* Refer to agency-specific guidance for acceptance of different NAMs.

Ideally the description of the relationship of the NAM to the biologic effect of interest should be based on available information on the relevant biology or mechanism of action for the endpoint of concern in the species of interest. In some cases, this may not be possible, and data from a different species than the one of interest may be the only available basis for comparison. However, the physiology of the species of interest may differ from the existing surrogate test species, further emphasizing the need to incorporate mechanistic understanding into the NAM evaluation. For example, anatomical and physiological aspects of the rabbit eye differ from human (Clippinger et al., 2021) and the windows of susceptibility during brain development differ among species (Smirnova et al., 2014; Tsuji and Crofton, 2012). Consequently, the biological relevance to the species of interest and key exposure considerations should be acknowledged in assessing both the NAM and the existing reference test method. Evaluations of biological and mechanistic relevance might consider, for example, the relevance of the cell type used, the physiological characteristics of the relevant organ/tissue under investigation, or the presence of species-relevant metabolites associated with the test substance (noting that metabolites found in one species might be different from those found in another or produced in a NAM). Additionally, one might examine the ability of a method to assess a particular species-specific mode of action or mechanism (Hartung, 2010; Madia et al., 2021; Parish et al., 2020).

Moving beyond species translation, variation between individuals (e.g., donors of cells or tissues used in in vitro assays) may additionally underlie biological variation that can both affect the measured response, as well as potentially add additional insight into inter-individual variability across a population (Harrill, 2020). While not covered extensively in the present document, NAMs users and developers should be aware that observation of an effect (with regards to magnitude and, in some cases, presence of the observed effect) as well as the point of departure or dose at which the effect occurs can be modulated by genetic sequence variation present across a panel of cell lines (Chiu et al., 2017). Use of genetically diverse cell line panels in cell-based tests can offer advantages in understanding the population dynamics of toxicity and phenotypic response (Harrill and McAllister, 2017), uncovering genetic sequence variants that confer susceptibility (Frick et al., 2015), enabling identification of uniquely susceptible subpopulations (Church et al., 2015), and facilitating measurement of toxicokinetic and toxicodynamic variability (Rusyn et al., 2022). While tumor-derived cell lines are sometimes used in in vitro models, their genetic composition may not adequately represent genetic variation in the population. Specific recommendations for incorporating diversity in NAMs will depend on context. Accordingly, fit-for-purpose study designs should be developed in cooperation with geneticists to ensure adequate coverage of target species variation, as well as with bioethicists and relevant stakeholder groups if human genetic variation will be queried (see for example ICCVAM, 2022). Specific recommendations for assessing inter-individual variation are beyond the scope of this report and will likely continue to evolve with the emerging science in this arena.

In some cases, complex AOPs or outcomes that are a result of more than one AOP may require that multiple aspects of the mechanism for the adverse outcome be assessed to obtain an adequate prediction of the outcome. NAMs generally have limitations that do not allow them to be predictive for or technically applicable to all chemical classes. The NAM may also be limited with respect to the complexity of the biology it can represent. Combining more than one NAM with differing performances, applicability, and biological coverages into defined approaches (DAs) can enhance their ability to predict outcomes (OECD, 2017). This can be achieved by mapping appropriate NAMs to key events along an AOP to ensure sufficient mechanistic representation to predict the relevant adverse outcome for the species of interest. An example of mapping NAMs to key events along an AOP resulting in a DA to address a regulatory endpoint is found in the OECD “Guideline No. 497: Defined approaches on skin sensitisation” (OECD, 2021a).

### 3.2.2 Reference Compounds

Reference compounds can have a broad range of potential purposes that span from running an assay through evaluating its technical quality and biological relevance as shown in Table 4. A reference compound may work well for one purpose but not be adequate for another. For example, a reference compound may work well for a certain method as a positive control (e.g., a developmental neurotoxicity assay) even if it would not result in the implicated adverse effect in the target species (e.g., due to an inability to pass through the blood-brain barrier) and thus may not be suitable as a biological endpoint reference compound. Depending on the COU, reference compounds may include monoconstituent chemicals, mixtures, or complex extracts (e.g., from medical devices).

Table 4 Selected Uses of Reference Compounds

Discrete Compound Sets^*^ | Purpose(s) | Criteria for Compound Selection
Positive Control(s) | Verify whether the method is performing as expected. | Compounds that have been verified to cause a reliable, measurable, and statistically significant change in a specific assay readout under the method conditions.
Performance Compounds | Assess the extent to which a new or modified method compares to a similar established method - “me-too”. | A set of compounds that reliably elicit a response (or no response) in the already established method.
Proficiency Compounds | Evaluate the performance of a new lab using an established method. | Compounds that reliably elicit a response (or no response) in the established method; can be a subset of performance compounds.
Biological Endpoint Reference Compounds | 1) Assess the biological relevance of a method.; 2) Compare agreement for methods designed to measure an outcome relevant to the same in vivo endpoint, but which use a different context (e.g., different species, method, or measurement modality). | 1) Compounds with evidence for in vivo effect (positive) or no effect (negative) for the endpoint of interest (ideally from the target organism of interest or a suitable comparator species).; 2) A common set of compounds that have been tested for the endpoint of interest in at least one reliable method.

* There may be overlap in eligible compounds across these sets.

A key aspect of demonstrating the scientific validity of a NAM is assessing its performance against existing test methods in use, often via testing biological endpoint reference compounds whose biological activities are well-characterized and understood. Biological endpoint reference compounds generally include compounds that have been demonstrated to produce adverse effects, ideally with a range of potencies, or not to produce such effects (Browne et al., 2019).

Identification of biological endpoint reference compounds with known effects for particular apical outcomes can be challenging. This is particularly true for humans, where data are often lacking, as the field of toxicology has been applied to prevent human exposure to potentially hazardous chemicals. Success in this effort means that limited human data are available, or such substances have not been adequately characterized or measured in human populations. When such human data are available, they may be from accidental exposures or low-level exposures, both of which often provide limited quantitative data on the exposure levels or outcomes. Case studies can provide indications of hazard but are often unsuited for establishing clear cause-effect correlations.

Despite these challenges, efforts should be made to identify compounds with human effects related to the outcome or mechanism being predicted by the NAM under development. Even if such data are limited in their ability to support quantitative evaluation of the method, they may provide a qualitative check on the relevance of the NAM. High-quality human epidemiological data can also be difficult to obtain and align with toxicological data; however, epidemiological data are useful in identifying environmental chemicals with strong associations to adverse human health effects. Evidence-based frameworks have been developed to allow compilation of vast amounts of information, followed by a transparent and objective selection of narrower, relevant data sets (Wikoff et al., 2020), thereby improving accessibility of data. These frameworks include systematic evidence maps, which provide broad overviews of an evidence base, and subsequent systematic reviews, which provide a more narrow and comprehensive assessment of a particular research question, allowing for more rapid integration of human epidemiological data with other sources of existing information (Wolffe et al., 2019). In combination with mechanistic lines of evidence and legacy animal data, these data might be used to define biological endpoint reference compounds to help establish scientific confidence in NAMs (see Krishna et al., 2021 for an example).

Where possible, compounds that have been shown to cause the relevant effect(s) in the species of interest should be used as positive controls during the assessment of NAM robustness and relevance. Petersen (2021) has described characteristics to consider when choosing positive controls (e.g., chemicals tested using in-process control measurements each time the assay is performed), and many of the same considerations will be relevant for reference compounds to assess a NAM. Both positive and negative biological endpoint reference compounds, performance compounds, and proficiency compounds should be included and should be selected with equal care. Due to historical bias in the literature emphasizing positive results (recognizing not all positives reported in the literature are true positives), reliable reference compounds that are negative for the target endpoint may be more challenging to identify. Data curation efforts focusing on negative results should be strongly considered for publication, and efforts that test compounds up to relatively high concentrations across a broad range of targets may provide valuable information to help resolve this issue.

All COUs may not be covered by one definitive list, and selection of reference compounds should consider the particular regulatory needs for that COU. In some cases, it may also be appropriate to define subsets of biological endpoint reference compounds with respect to the mechanism being evaluated (rather than the apical endpoint) for each NAM within a battery. For example, few compounds qualify as reference compounds for developmental neurotoxicity, and instead each process evaluated in the battery (e.g., proliferation or neurite outgrowth) has its own assay-specific biological endpoint reference compounds. Consequently, a biological endpoint reference compound may be positive in one assay but negative compound for another assay that is evaluating different mechanisms or processes.

Lists of reference compounds (e.g., for assessing transferability) are required in the formal validation process outlined by the OECD. However, the compilation of reliable reference compounds is time-consuming and resource-intensive. Efforts to facilitate the rapid development of curated lists of reference compounds via rigorous systematic reviews and automation processes where feasible have allowed more robust evaluation of NAM sensitivity and specificity (Judson et al., 2019; Thomas et al., 2019). An example of a biological endpoint reference compound list for NAM qualification can be found in the 2021 FDA revision of the International Council for Harmonization of Technical Requirements for Pharmaceuticals for Human Use (ICH), S5(R3) Detection of Reproductive and Developmental Toxicity for Human Pharmaceuticals Guidance for Industry (FDA, 2021b). The list includes compounds with positive and negative outcomes. The guidance notes that these compounds, as well as others, can be used to support qualification of an alternative assay or battery of assays for particular COUs.

### 3.2.3 Comparison to Existing Laboratory Animal Methods

The standard for establishing scientific confidence in a NAM and gaining regulatory acceptance has generally included consideration of whether the NAM can provide information on equivalent or better usefulness, scientific quality, and/or relevance than the existing test method used for regulatory decision-making (as appropriate within each agency’s regulatory framework). For example, a criterion in OECD GD 34 for validating any new test method is “the method generates data for risk assessment purposes that are at least as useful as, and preferably better than, those obtained using existing methods. This will give a comparable or better level of protection for human health or the environment” (OECD, 2005). The amended U.S. Toxic Substances Control Act (section 4(h)(1)(B)) includes specific considerations for NAMs and mandates that the EPA encourage and facilitate the “use of scientifically valid test methods and strategies that reduce or replace the use of vertebrate animals while providing information of equivalent or better scientific quality and relevance that will support regulatory decisions” (15 USC §2601, 2016).

Historically, the concept of “equivalent or better” has relied upon a direct comparison with the traditional animal test data. However, to achieve the goal of “better” information, it must be acknowledged that NAMs may not provide the same information generated by the traditional animal test method and the results of the NAM may not directly align with the results of the traditional animal test (for examples, see Clippinger et al., 2021; Hoffmann et al., 2018, 2008; ICCVAM, 2018; Kolle et al., 2017; Petersen et al., 2022b; Piersma et al., 2018; Prior et al., 2019; Sewell et al., 2017). In some instances, the NAM may provide biologically relevant information, mechanistic insights, or sufficiently sensitive endpoints that are adequate for the regulatory decision-making process, and a comparison to data from traditional animal test methods may not be necessary. For example, some pharmacologic or toxicologic targets may not exist in nonhuman species, so animal studies may not be relevant for assessing potential human effects mediated through such targets. Human-based NAMs might provide biologically relevant information in these cases. Furthermore, NAMs often provide mechanistic information rather than data on apical endpoints measured in animal test methods (e.g., while an observed reduction in body weight in an animal may not elucidate the underlying mechanism of toxicity, NAMs may be able to provide these mechanistic insights). There are also circumstances in which the animal model may be measuring a complex biological endpoint that is relevant to the COU but is not adequately covered by the NAM in question. In these cases, a comparison to traditional animal test methods may be the most expedient option, particularly where the mechanism is not fully understood. The objective of the evaluation of the NAM is to demonstrate that the NAM provides information that leads to a similar regulatory decision as would be made based on existing methods.

Comparisons between NAMs and existing laboratory animal methods, as appropriate, should consider the reliability and reproducibility of the reference animal test methods, including understanding reasons for observed variance in both types of methods, if possible. When available, using reference data from the species of interest allows the assessment of a NAM against the species-relevant response. If in vivo time-course data are available, NAMs such as microphysiological systems can be used to simulate toxicokinetics and then computational extrapolation of the microphysiological system can be compared with the animal or human data. Physiologically based pharmacokinetic modeling allows for the estimation of internal concentrations from reference doses and comparison to activity concentrations in vitro. These models can also be applied in a reverse dosimetry approach to perform in vitro to in vivo extrapolation (IVIVE) and predict equivalent administered doses that would result in plasma, or target tissue, concentrations where bioactivity is observed in the NAM. When humans are the species of interest, high-quality epidemiological, clinical, or observational evidence of effects may be useful to provide insight on building scientific confidence for the NAM. However, such human reference data are rarely available for most endpoints and chemicals, and comparisons must often rely upon data from a different species. Data from animal studies can be curated and compared to yield reference standard lists with reproducible, robust, and relevant results. In some contexts, such as ecological applications, sequence homology of molecular targets or conservation of biological mechanisms may be helpful to support a comparison to data derived from different species (Farmahin et al., 2013; LaLone et al., 2016).

Several publications have assessed the results of animal-based reference test methods for a range of endpoints and showed that the results from these tests demonstrate varying level of reproducibility (Browne et al., 2018; Dumont et al., 2016; Karmaus et al., 2022; Kleinstreuer et al., 2018; Luechtefeld et al., 2016; Pham et al., 2020; Rooney et al., 2021). The observed variability could reflect inherent biological factors, reporting errors, protocol differences, or variations in test substance purity, for example. Conflicting results between reference animal test method and NAM data should be explained whenever possible, including reference to the biology of the species of interest. This is necessary to provide a realistic context about the capabilities of the laboratory animal data, and therefore, set appropriate expectations around the maximum performance capacity of NAMs that are compared against the reference test method (Browne et al., 2019).

The relative value of comparing NAMs to legacy animal tests and the biological and mechanistic relevance to the species of interest of the NAMs should be considered based on the quality of the available data. Realistically, in many cases those seeking to establish confidence in a NAM need to consider the historical use of animal studies and the requirement for comparison to existing methods as one important line of evidence. Under many statutory and regulatory requirements, information derived from NAMs must not be less protective than existing methods. Ideally, the method will be more predictive, and may allow for more rapid and comprehensive generation of relevant data across many chemicals where data may otherwise be scarce or absent, thereby engendering confidence among regulators and stakeholder communities. There may be specific COUs that allow for exceptions to this rule; however, acceptance of such NAMs as qualified methods will be subject to the specific requirements of the relevant agency or regulatory body. The extent of such comparisons may vary depending on the quantity and quality of the available data and the depth of understanding of relevance to the species of interest, of both the NAM and the reference method. When the NAM performance is assessed based on the reference animal test method, the amount of acceptable variance in the NAM must be considered relative to the variance observed in the in vivo data and based on the intended COU.

## 3.3 Technical Characterization

Technical characterization is a key component of developing NAMs for widespread use. It includes an assessment of sources of variability in the NAM, designing the assay to include relevant control measurements, evaluating the range of test substances for which the assay can be used (i.e., the applicability domain), and developing a suitable statistical data analysis approach. A key aspect of demonstrating the scientific validity of a NAM is that the assay is sufficiently well-characterized from a technical perspective to ensure that it is robust, reliable, and reproducible. The NAM includes both the test system itself and the method of quantification of the endpoint. There are aspects of technical characterization that overlap with previous key concepts such as biological relevance, which informs the selection of reference compounds for different purposes (Table 4). Examining the performance of a NAM against a well-defined set of biological endpoint reference compounds with relevant bioactivities has already been presented (Section 3.2.2), so this section will focus on technical aspects such as quality tools (Ishikawa, 1985), method development, documentation, and standards.

### 3.3.1 Incorporation of Selected Quality Tools

Overall, the technical characterization of NAMs fits into a framework with overarching steps (Figure 2): 1) initial vetting of the scientific relevance of the NAM, 2) conceptual evaluation, 3) within-laboratory evaluation, 4) statistical data analysis and reporting, and 5) interlaboratory evaluation (if needed^1^). Results from steps 2 through 5 are interrelated, with results from each step potentially impacting all the others. For example, results from interlaboratory testing could reveal that additional intra-laboratory testing should be performed or that the protocol needs to be revised to include a new control measurement.

Figure 2 Framework for developing robust NAMs. Solid lines indicate steps that should be taken in the suggested order. Dotted lines indicate a direction that can be taken, if necessary, to reevaluate any of the previous steps. Adapted and reprinted with permission from Petersen et al. (2022b).

Figure 2. Steps for further developing a scientifically relevant NAM are described in the following text.

The initial vetting step includes an evaluation of the biological relevance of an assay, its potential COU, and the potential to reach a sufficient level of technical quality. If the NAM lacks a clear COU or biological relevance or has significant technical quality issues that potentially cannot be resolved, the NAM may not be suitable for regulatory use. In the conceptual evaluation phase, the NAM is reviewed to assess expected sources of variability and design control measurements. In the intra-laboratory evaluation, experiments can be performed to assess the robustness of the assay, establish a typical range for the control measurements (e.g., negative, vehicle, and positive controls), and identify if there are interactions between control measurements and the test result. Information from the conceptual evaluation and the intra-laboratory evaluation enable design of a statistical model to evaluate the mean assay result, characterize variability, and establish criteria for a positive or negative response and the statistical confidence for this determination.

Lastly, it may be necessary for some NAMs to undergo an assessment of transferability through interlaboratory testing. Interlaboratory testing can potentially reveal steps in a protocol that are interpreted differently among laboratories and revisions that can be made to improve the NAM’s technical quality. Transferability studies can also identify issues that arise from differences in technical implementation or execution of a protocol (e.g., pipetting in one lab vs. automation in another) that necessitate changes.

Table 5 lists several quality tools that can be helpful in technical characterization of a NAM. A more detailed treatment of this topic is available in Petersen et al. (2022b). Some of the information generated from these tools may remain internal with the test method developer, while other information may be requested to support agency review.

Table 5 Quality Tools Often Used in Technical Characterization of NAMs^*^

Quality Tool | Description | Benefit/Utility
Flowcharts | Diagram every step in a protocol. | Optimize identification and coverage of protocol steps that can be monitored by control measurements.
Cause-and-Effect Analysis | Review literature and assay background; diagram all expected sources of variability. | Identify key sources of variability and aspects of a method that may be challenging to standardize. Guides robustness testing and selection of control measurements.
Control Charts | Control measurements to assess technical performance, including one-time preliminary experiments, periodic measurements at a predetermined frequency, and in-process control measurements made each time the assay is performed. Control charts monitor control measurements across time. | Test for potential biases, evaluate instrument performance and calibration, and measure key sources of variability across time and among experiments.
Check Sheets | Record key data, metadata, and control measurements. | Monitor in-process control measurements and support troubleshooting when issues arise, support data analysis and reproducibility.
Scatterplots | Plot all data from control measurements and test substance results. | Assess if there is an interaction between different in-process control measurements or between those control measurements and test substance results.

* Details and examples can be found in Appendix B.

### 3.3.2 Best Practices for Quality Control

This section describes technical factors that federal agencies may consider as best practices for the evaluation of NAMs, including DAs and Integrated Approaches to Testing and Assessment (IATAs). Factors listed here may or may not apply to all NAMs. Furthermore, other factors not listed in the guidance, such as additional information or testing, may be needed by an agency when evaluating the NAM. Developers and/or sponsors are encouraged to communicate directly with the federal agency to which they intend to submit methods or data to determine additional factors that may be necessary for review.

A submission of a NAM for regulatory evaluation should include a description of any intra-laboratory or interlaboratory studies, if conducted. It should state whether the NAM was compared to a reference method: another NAM, in vivo animal data, or human data. Information on the reference method being used for comparison (i.e., reference data set) may also be needed during evaluation. Evaluation of a NAM can be accomplished via several different processes and involves documenting, using specific laboratory investigations, that the performance characteristics of a method are suitable and reliable for the intended application(s). The acceptability of data relates directly to the criteria used to evaluate the method.

In addition to serving to document the performance and characterize the applicability of the NAM, good scientific, technical, and quality practices ensure that the overall evaluation process is efficient and effective, leading to increased confidence in the proposed method. Developers should retain all information necessary to calibrate, operate, and maintain any equipment, such as equipment and software manuals, quality and safety confirmation certificates and warranties, documentation of software versions, modeling algorithms, curated databases, and training sets. Developers should also maintain documentation of suppliers for materials, cells, and reagents if this information is relevant for evaluation of a NAM (discussed in detail in Section 3.3.3). For further details on quality practices, equipment procedures, and documentation to retain, see the OECD Guidance Document on Good In Vitro Method Practices (GIVIMP; OECD, 2018). An Installation Quality/Operation Quality/Performance Quality (IQ/OQ/PQ) report for each instrument used is recommended and is required if the studies are intended to be Good Laboratory Practice (GLP)-compliant.

#### 3.3.2.1 Relevant Information for Cell/Tissue Methods

Documentation of the origins of cells and tissues used in any test method should be maintained. Information retained for review should ideally include (but not limited to):

- Ethical, legal and safety considerations
- Species / strain / sex
- Demographic information (if relevant)
- Source / supplier
- Number of donors
- Organ / tissue of origin
- Cell type(s) isolated
- Sequences of engineered molecular targets, where applicable
- Isolation technique and date
- Biosafety classification
- Cell line identification and authentication
- Serological testing for infectious agents (e.g., mycoplasma testing)
- Number of cell culture passages/population doubling
- Doubling time
- Genetic stability
- Genetic and protein expression information (if relevant)
- Pretreatment

For more detailed information, see the GD on Good Cell and Tissue Culture Practice 2.0 (Pamies et al., 2022) and the OECD GIVIMP document (OECD, 2018).

Documentation about quarantine of new cells and tissues in proper storage conditions in the laboratory prior to use in testing should be provided. Assays utilizing live cells or tissues should include a cell viability assay.

Records and documentation for the performance of all laboratory equipment (plate readers, incubators, refrigerators/freezers, etc.) should be maintained by all participating laboratories.

Registering cells in cell banks can help with traceability and long-term availability. The cell banks should include documentation of cell density and cell passage number. Records of reagent preparation should be maintained (e.g., using check sheets to track any reagent or consumable used). This is also relevant to in vitro methods not using cells/tissues. Some examples are (but not limited to):

- Supplier
- Catalog number
- Batch / lot numbers
- Dates of preparation
- Expiration dates
- Analyst name

The sponsor or developer of the study should provide all safety information as it pertains to the method or methodology being developed, as well as all relevant regulations for the use, transport, and disposal of all hazardous materials.

#### 3.3.2.2 Assessing the Analytical Method Used in the NAM

The developer should provide data that clearly demonstrates the substance detected or quantified is the intended chemical or analyte of interest. Table 6 lists and describes best quality control practices relating to analytical methods.

Table 6 Analytical Method Assessment^*^

Analytical Method Assessment | Description | Benefit/Utility
Limits of Detection and Quantification | The lowest quantity or concentration of an analyte that can be reliably detected or quantified above the reagent blank or within the standard curve. The highest concentration on the standard curve determines the upper limit of quantification. | Establish the range of an analytical method.
Identification of Interference | Identifies when components of the method falsely alter the detected signal. | Determines if there are interactions between method components and prevents reporting of artifactual results.
Assessing Analytical Precision | Characterizes precision of the analytical method used and any other tests of precision, such as those assessing performance variability when different personnel use the proposed method or when different instrumentation is used for the method. This can be evaluated by interlaboratory comparison studies. | Builds confidence in the reliability of the analytical method and evaluates sources of laboratory variability.
Stability of Materials Used in NAMs | The ability of materials used in the NAM (e.g., test substances, testing apparatus, exposure system, reagents, and analytes) to produce similar and acceptable results over a period of time in a given environment. | Characterizes method materials and ensures reliable data is consistently obtained for a particular method.
Robustness Testing | Tests the ability of a method to be reproduced under different conditions or circumstances without the occurrence of unexpected differences in the obtained results. | Determines the range of parameters in which the assay works acceptably.
Analysis of Recovery | Tests an extraction method by comparing the results of the extracted samples with those of spiked samples of a similar matrix and/or spiked blanks. | Verifies the efficiency and reproducibility of an extraction method.
Technical Analysis of the Applicability Domain | Obtains adequate test method data for chemicals and/or products representative of those relevant to the specific COU for which the test is proposed and clearly describe the physicochemical properties of the applicability domain. | Reduces uncertainty regarding the assay performance for use with different chemicals and/or products and provides methods and criteria for determining when a chemical is within the applicability domain.
Positive Control | Identify positive control compound(s) relevant to the endpoint and within the detection window of the assay. | Provides a consistent and trustworthy basis for comparison for test substance results.
Reference Standards for Instrument Calibration | Used to calibrate instruments using calibration standards and/or quality control samples. | Ensures reliable measurements and identifies potential sources of uncertainty.
Setting Specifications | Set specifications for in-process control measurements based on intra-laboratory and/or interlaboratory test results using a statistical approach. | Ensures sufficiently stringent criteria for control measurements leading to robust test substance results and lack of bias.

* Details and examples can be found in Appendix C.

#### 3.3.2.3 Assessing Accuracy and/or Concordance of the NAM with Performance Standards

Accuracy and concordance are very similar in definition and are often considered to be interchangeable depending on the context in a given document or passage. Concordance is often defined as the comparison of two methods or tests based on the results obtained, while accuracy is often defined as the comparison of a method or test to a reference method or test result. An assessment of accuracy and/or concordance is often used in the statistical evaluation of test methods and associated data. In this context, accuracy is defined as the proportion of correct predictions among the total number of results. Other statistical parameters used when discussing the accuracy or concordance of methods include sensitivity, specificity, positive and negative predictivity, and false positive and false negative rates.

Whenever possible, well-defined performance standards (e.g., a balanced set of reference substances known to yield positive and negative results) can be used to check response and method validity. Quantitative measures of concordance (i.e., sensitivity, specificity, positive and negative predictivity, false positive, and negative rates) should be reported. When comparing a proposed test method to that of a method with established performance standards (e.g., “me-too” methods for OECD test guidelines [TGs]) that produces functionally and mechanistically similar data, the concordance (including discordant data) of both methods should be evaluated against one another and against a reference method.

#### 3.3.2.4 Standard Operating Procedures and Method Details

It is recommended that the proposed test method have well-documented standard operating procedures (SOPs) to support consistent performance of the method and related laboratory activities such as test system handling and equipment calibration. SOPs should cover all aspects of testing and analysis. The SOPs should include:

- Accountability systems that ensure integrity of test articles (e.g., record keeping, security, and chain-of-sample custody).
- Sample preparation and analytical tools, such as methods, reagents (including, when applicable, the manufacturer, catalog number, lot number, etc.), equipment, and instrumentation.
- Procedures for quality control and verification of results.
- Method details, including complete product description and formulation, exposure system, test substance volume/weight/solubility/dosing protocol, and appropriate exposure/dose range.

The submitting party should also provide a list of operating characteristics and operational criteria for judging test performance and results. Operational information and criteria for the technical systems that comprise the NAM may vary, but the criteria could include quality control charts or other performance standards for all controls, standards, exposures (dose and duration), and experimental groups. A description of the statistical methods used to assess the data should be included. In addition, developers should describe how experimental uncertainty, statistical uncertainty, interference, and background were assessed.

### 3.3.3 Documentation

This section describes best practices for the documentation of NAMs (including DAs and IATAs). Factors listed here may or may not apply to all NAMs. Furthermore, additional documentation may be needed by an agency to evaluate the NAM. Developers and/or sponsors are encouraged to communicate directly with the federal agency to which they intend to submit methods or data to ascertain additional factors that may be necessary for review. For some agencies, independent peer review of the NAM and associated data may be needed prior to agency review.

For new methods, documentation should include a description of the proposed test method and how it may be relevant for regulatory purposes or would fit into a specific COU. Relevant information would include (but not be limited to) any mechanistic information and biological relevance of the test method and any proposed COU (e.g., applied to risk assessment). Human or appropriate taxa applicability domains should be included in the documentation. Other important aspects for documentation are detailed below.

Additional resources are available that provide guidance on documentation. For in vitro methods, developers can consult the OECD GIVIMP document (OECD, 2018).

#### 3.3.3.1 Test Substance Identity and Purity

For all substances tested in the NAM (e.g., controls, reference compounds, other test substances), at a minimum, the substance(s) identity, ideally a unique identifier (e.g., CASRN, SMILES, InChIKey), and information on purity of the substance as provided by the supplier should be reported. If the laboratory has the necessary capabilities, there is added benefit in performing additional quality control measures using analytical methods to assess the purity and identity of the substance. The ability to collect this information may also depend on the COU, as some test substances (e.g., environmental samples that represent complex mixtures with unknown or variable composition) may not be well-characterized.

#### 3.3.3.2 Method Development

A specific, detailed, written description of the method should be developed based on data produced from that method. This can be in the form of a protocol, study plan, report, and/or SOP. Each step in the method should be investigated to determine the extent to which environmental, matrix, or procedural variables could affect the detection and/or quantification of the analytes.

During development close attention should be given to factors such as:

- Reagent selection (with appropriate biological relevance, specificity, and stability).
- Detection method or instrumentation (i.e., performance and calibration procedures readily available).
- Compatibility of disposables (i.e., microtiter plates and other plastics) with the assay measurements and test substances.
- Analysis method / statistical method.
- Steps or processes that could introduce assay variability.

Appropriate steps should be taken to minimize external or matrix effects (or at least characterize those effects) throughout the application of the method, especially if compounds, matrix, or equipment used during development are different from those used during technical characterization of the method.

#### 3.3.3.3 Endpoint and Parameter Measurements

Measurements of each endpoint or analyte should be well tested and documented. Method development for a novel NAM should include demonstration that the method can successfully measure all relevant parameters. Relevant metadata for each experiment should be captured and recorded to link quantitative data to qualitative information, such as experimental conditions or test chemical and concentration, and to track external factors (such as the date or technician conducting the experiment) that may contribute to assay variation or batch effects. These data and metadata should be exported and saved in an accessible format so that they can be referenced during independent reviews of the validation. This topic is also discussed in the sections in Appendix B on control charting and check sheets.

#### 3.3.3.4 Limits of Use

The specific strengths and limitations of the test method should be clearly identified and described. Any potential sources of interference should be listed, and any chemicals or classes of chemicals with the potential to interfere with the test should be identified. The documentation should also identify any known limits on what materials can be tested using the NAM.

#### 3.3.3.5 Well-Defined Endpoint

Data generated by the test method should adequately measure or predict the endpoint of interest, and that endpoint should be clearly defined with an explanation of biological relevance as described in Section 3.2. An example of this would be a NAM that provides information about a specific key event in an AOP. The data should also describe any linkage between the new test method and an existing test method or between the new test method and effects in the target species. Criteria for a positive, negative, or inconclusive result in the NAM should be clearly defined and assessed over time to ensure stability of the system.

#### 3.3.3.6 Building a Statistical Model

Statistical models can be built using data from the intra-laboratory testing. These models can be built using either Bayesian or frequentist statistical approaches. Histograms can be used to assess the distribution of data obtained for in-process control measurements and to evaluate what type of distribution (e.g., normal distribution) fits the data (see Petersen et al., 2022b for details). It is helpful to develop models to calculate cumulative variability of the NAM from measurements of both test substances and in-process control measurements instead of only using data on variability from the test substances. This information can be used to build a statistical model that can yield a decision (e.g., is the test substance positive or negative) and the statistical confidence for that decision. A simple comparison of the mean value from a test substance assessment to a threshold does not consider the variability of the test results and cannot provide statistical confidence for the decision.

One key concern when developing statistical models for NAMs is how to differentiate between “negative” and “weakly positive” results. The threshold for the statistical model can be informed by in vivo data when available (Friedman et al., 2023; Karmaus et al., 2022; Pham et al., 2020). This may require repeated testing of “borderline” compounds to assess the NAM reproducibility; see for example Guideline 497 (OECD, 2021a). For example, a statistical model evaluating a dose-response relationship may be used to assess the point of departure or the concentration that causes a defined effect (e.g., EC_50_ value) and associated data-driven confidence intervals around those values. It may also be relevant to evaluate the quality of a NAM using statistical approaches such as a T-test, Z-factor, or other appropriate statistical criteria (Zhang et al., 1999; Zhang, 2011).

#### 3.3.3.7 Reproducibility of the Assay Results

Documentation of technical reproducibility should be included with the information submitted, where applicable. The reproducibility of the method can be assessed by replicate measurements, including quality controls and samples. This assessment should include discussion of the rationale for the selection of the substances used to evaluate reproducibility (possibly in any intra- and interlaboratory studies conducted), and the extent to which they represent the range of possible test outcomes. Outlier values should be identified and discussed. A quantitative statistical analysis of the extent of any intra- and/or interlaboratory variability or coefficient of variation analysis should be included. Measures of central tendency and variation should be summarized for historical control data (negative, positive, and vehicle where applicable). When testing the same compound(s) multiple times, comparisons can be quantitative (e.g., EC_50_ values obtained) or qualitative (e.g., hazard classification). In cases where the proposed test method is mechanistically and functionally similar to an established test method with existing performance standards (e.g., from an OECD TG), the reliability of the two test methods should be compared and the potential impact of any differences discussed.

#### 3.3.3.8 Data Interpretation Procedure

The data interpretation procedure, including criteria for positive and negative responses, should be clearly described for each NAM. Combining NAMs into DAs requires fixed data interpretation procedures that are objective and do not include expert judgment, ensuring that they will result in the same outcome when applied by different groups (OECD, 2017). Use of computational algorithms, e.g., machine learning models, and software (including version number) should be well-documented to ensure reproducibility of the conclusions.

## 3.4 Data Integrity

Data integrity is a key aspect of ensuring that information derived from NAMs is trustworthy and reliable. Method developers are advised to conduct an internal evaluation of the processes used for the acquisition, transferring, and processing of raw data before those data are submitted to external, independent parties for assessment and peer review to ensure data integrity and credibility of results. Studies should be conducted to the extent possible according to principles of GLP (21 CFR § 58; 40 CFR § 160; 40 CFR § 792; OECD, 1998), where required. Furthermore, evaluating bodies, such as the National Toxicology Program Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM) can facilitate assessments of the quality and integrity of the development process of the NAM (NIEHS, 2023b). Other resources are available that provide guidance on maximizing data integrity. For in vitro methods, developers can consult the OECD GIVIMP document (OECD, 2018). For digital tools and management of digital data, developers can follow the “FAIR Guiding Principles for scientific data management and stewardship,” published in 2016 (Wilkinson et al., 2016).

## 3.5 Information Transparency

Transparency facilitates trust in the use of NAMs and thereby hastens the pace of an agency’s regulatory decision-making process and potential regulatory acceptance or qualification. A NAM’s relevance to the species, COU, and technical characterization should be transparently communicated to peer reviewers, the scientific community, and to the public. Where appropriate, peer-reviewed articles and information describing the COU, biological relevance, and technical characterization of the NAM should be published in open-access journals and/or summarized in public-facing regulatory documents. Ideally, the principles of the NAM, the protocol, raw data files and scripts used to analyze and graph data, and the reporting standards should be communicated publicly. For NAMs that contain intellectual property, the OECD provides tools to maintain transparency, including reasonable and non-discriminatory terms for licensing commitments (OECD, 2021b). The use of proprietary or patented techniques or equipment in a method can potentially be used to fulfill regulatory testing needs. For some agencies, there may be a need for the NAM developer to convey proprietary or patented information to support regulatory acceptance or qualification; agency-specific guidance can direct test method developers about the agency’s information needs.

Partners within the International Cooperation on Alternative Test Methods (ICATM; NIEHS, 2023c) publish information on NAM assessment and peer review via the Tracking System for Alternative methods towards Regulatory acceptance (TSAR) (EURL ECVAM, 2021). TSAR indicates the stages NAMs have reached in terms of acceptance as a recognized standard for use in a regulatory context together with a summary description and accepted protocol(s) or SOP(s). Where available, TSAR also includes relevant records and documents associated with a NAM linked to the different steps of the entire process: submission, validation, peer review, recommendations and regulatory acceptance or qualification. How to interpret the data that a NAM generates, and associated acceptance criteria, should be clearly communicated so that end users understand the process and can apply it in a practical setting.

## 3.6 Independent Review

Information and data supporting the NAM’s COU, biological relevance, and technical characterization may be scientifically reviewed by independent third parties (whose members do not have conflicts of interest); however, the necessary level of review will depend on each agency’s regulations and policy.

Evaluation of a NAM can be accomplished via several different processes and involves documenting the performance characteristics of a method to determine whether they are suitable and reliable for the intended application(s). A method’s reliability often includes (but is not limited to) reproducibility, repeatability, and robustness. However, there may be additional information not listed in this report that may be necessary for the review of some methods. In addition to the performance and applicability of the NAM, good scientific, technical, and quality practices ensure that the independent review process is efficient and effective and leads to increased confidence in the proposed method. Laboratories should retain all information relevant for evaluation of a NAM, such as information necessary to operate and maintain the equipment used in the conduct of a NAM (e.g., equipment and software manuals and quality and safety conformation certificates), as well as documentation of suppliers for materials, cells, and reagents. For studies intended to be GLP-compliant, an IQ/OQ/PQ report for each instrument used may also be relevant. For non-GLP studies, documentation of proper installation and testing to show equipment performs as intended should be retained.

Raw data from and information describing the NAM should be accessible for review by independent third parties and/or regulatory agency decision-makers. The assessment and independent peer review of NAMs may be organized by validation bodies, such as NICEATM, the European Union Reference Laboratory for Alternatives to Animal Testing (EURL ECVAM) and its Scientific Advisory Committee, and the Japanese Center for the Validation of Alternative Methods (JaCVAM). Other bodies or international organizations that can independently review NAMs include the U.S. Federal Insecticide, Fungicide, and Rodenticide Act Scientific Advisory Panel, the European Food Safety Authority Scientific Committee, and OECD. Alternatively, the developer can fund (but not directly lead management of) an independent review of the method. Peer-reviewed publications are useful for sharing assay information with the scientific community and can supplement a more formal review by independent third parties to support acceptance and use of the method in a regulatory context.

The extent of independent review will vary depending on the COU, the regulatory framework, and the specific method being evaluated. Some of the information sent by the developer for independent review would include records from any intra- or interlaboratory studies, including whether the NAM was compared to another NAM, in vivo animal, or human data. These evaluations can potentially assist in the interlaboratory transferability of the NAM.

1 There could be examples of methods for which interlaboratory evaluation is not needed or not feasible, such as large scale roboticized high-throughput screening assays and machine learning-based in silico approaches.