# 2.0 Key Concepts in Flexible, Fit-for-Purpose NAMs Validation

The underlying principles of validation as described in OECD GD 34 remain essential, but the processes used for validation should allow for efficient and timely development of NAMs that are fit-for-purpose, reliable, and provide information relevant to the species of interest. Specifically, OECD GD 34 states that “new test methods undergo validation to assure that they employ sound science and meet regulatory needs,” i.e., that the methods are fit-for-purpose, which in addition to informing regulatory decisions, could include screening and prioritization of use cases. The guidance also states that “the validation process should be flexible and adaptable” and that performance must be “demonstrated using a series of reference chemicals” and “evaluated in relation to existing relevant toxicity data” (OECD, 2005). As such, confidence in NAMs should not be considered a universal status bestowed following the completion of a specific process (e.g., considering a NAM to be “validated” following successful completion of a ring trial study); instead, establishing confidence in NAMs should be viewed as an evolving and iterative process that requires communication among method developers, regulatory decision-makers, and validation bodies (ICCVAM, 2018).

Figure 1 Key concepts to consider during development and implementation of flexible, fit-for-purpose NAMs validation strategies. Adapted from van der Zalm et al. (2022).

Figure 1; refer to caption and following text for detailed explanation.

There are several key concepts that are important to consider when designing and implementing flexible, fit-for-purpose validation strategies, represented in Figure 1. These concepts are broadly applicable to the use of NAMs for various purposes but should be tailored as needed for the specific scenario and application. One overarching concept to consider is COU, or the purpose for which the NAM is intended (e.g., screening, hazard identification, potency evaluation, point of departure for quantitative risk assessment, etc.). The COU will inform the flexibility of the validation process and how the fitness of the NAM for a specific COU is established. Key concepts involved in that flexible, fit-for-purpose validation process are biological relevance, technical characterization, data integrity, and information transparency. As demonstrated in the figure, these aspects are related and interdependent. Finally, all parts of the validation process must be subject to independent review. These key concepts are similar to the essential elements proposed by van der Zalm et al. (2022) in a framework for establishing scientific confidence in NAMs, but we are adapting them here to be useful for a wider range of NAM applications. Each of these key concepts is further detailed in Section 3.0.