# 1.0 Introduction

The Interagency Coordinating Committee on the Validation of Alternative Methods (ICCVAM) is composed of representatives from 17 U.S. federal regulatory and research agencies that require, use, generate, or disseminate toxicological and safety testing information. ICCVAM conducts technical evaluations of new, revised, and alternative safety testing methods and integrated testing strategies with regulatory applicability. ICCVAM also promotes the scientific validation and regulatory acceptance or qualification of testing methods that accurately assess the chemical safety and hazards of relevant products in an effort to replace, reduce, or refine (enhance animal well-being and lessen or avoid pain and distress) animal use.

Shortly after its establishment as a standing committee in 1997, ICCVAM published a report, “Validation and Regulatory Acceptance of Toxicological Test Methods” (ICCVAM, 1997), outlining criteria for the validation and regulatory acceptance for new and alternative test methods. Additional guidance was subsequently provided in the 2003 publication, “ICCVAM Guidelines for the Nomination and Submission of New, Revised, and Alternative Test Methods” (ICCVAM, 2003). The principles outlined in these documents were carried forward in developing international criteria described in the Organisation for Economic Co-operation and Development (OECD) Guidance Document (GD) 34, “Guidance Document on the Validation and International Acceptance of New or Updated Test Methods for Hazard Assessment,” (OECD, 2005). These resources described a validation model that is flexible in principle, but in practice has demonstrated various limitations such as being lengthy and resource-intensive. For some contexts of use, methods may not need to undergo every step of this validation process to yield valuable data for a federal agency. Moreover, these documents are not always compatible with many modern approaches to toxicity testing, which place less emphasis on replacement of in vivo tests with a single alternative method and more emphasis on integrating results from multiple in vitro and in chemico assays and in silico approaches (e.g., computational models). The 2018 ICCVAM publication, “A Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products in the United States” (ICCVAM, 2018), provides a conceptual framework promoting better communication between agencies and test method developers and more flexibility in how confidence is established, to help ensure the adoption of new methods by federal agencies and regulated industries once validated for a specific application or context of use (COU).The text that follows provides more specific insight on establishing confidence in new approach methodologies (NAMs) building upon the principles outlined in the 2018 ICCVAM Roadmap.

In the context of this report, the term NAM refers to any technology, methodology, approach, or combination thereof that can be used to provide information on chemical hazard and risk assessment and supports replacement, reduction, or refinement of animal use (3Rs). This report builds on the principles articulated in existing guidances and documents (Table 1) accepted by the U.S. and internationally to advocate a more flexible approach to building confidence in NAMs. Here we present key concepts of validation, qualification, and regulatory acceptance as they apply to NAMs that include testing in a biological system (e.g., in vitro, certain in chemico, small model organisms), recognizing that additional considerations may be needed for other types of NAMs, such as computational model predictions (OECD, 2007).

Table 1 Examples of Existing U.S. and International Documents Related to Validation, Qualification, and Regulatory Use of NAMs

Document Title | Reference
Validation and Regulatory Acceptance of Toxicological Test Methods (retired as of publication of this report) | ICCVAM, 1997
ICCVAM Guidelines for the Nomination and Submission of New, Revised, and Alternative Test Methods (https://ntp.niehs.nih.gov/sites/default/files/iccvam/suppdocs/subguidelines/sd_subg034508.pdf) | ICCVAM, 2003
OECD Series on Testing and Assessment No. 34: Guidance Document on the Validation and International Acceptance of New or Updated Test Methods for Hazard Assessment (https://one.oecd.org/document/ENV/JM/MONO(2005)14/en/pdf) | OECD, 2005
Recommended Procedures Regarding the CPSC’s Policy on Animal Testing (https://www.cpsc.gov/Business--Manufacturing/Testing-Certification/Recommended-Procedures-Regarding-the-CPSCs-Policy-on-Animal-Testing) | CPSC, 2012
FDA Predictive Toxicology Roadmap (https://www.fda.gov/science-research/about-science-research-fda/fdas-predictive-toxicology-roadmap) | FDA, 2017a
Qualification of Medical Device Development Tools: Guidance for Industry, Tool Developers, and Food and Drug Administration Staff (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/qualification-medical-device-development-tools) | FDA, 2017b
EPA Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program (https://www.epa.gov/sites/default/files/2018-06/documents/epa_alt_strat_plan_6-20-18_clean_final.pdf) | EPA, 2018
ICCVAM Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products in the United States (https://ntp.niehs.nih.gov/sites/default/files/iccvam/docs/roadmap/iccvam_strategicroadmap_january2018_document_508.pdf) | ICCVAM, 2018
Guidance Document on Good In Vitro Method Practices (GIVIMP) (https://doi.org/10.1787/9789264304796-en) | OECD, 2018
Guidance for Industry and Test Method Developers: CPSC Staff Evaluation of Alternative Test Methods and Integrated Testing Approaches and Data Generated from Such Methods to Support FHSA Labeling Requirements (https://www.regulations.gov/document/CPSC-2021-0006-0001) | CPSC, 2020
Qualification Process for Drug Development Tools Guidance for Industry and FDA Staff (https://www.fda.gov/media/133511/download) | FDA, 2020
EPA New Approach Methods Work Plan (https://www.epa.gov/system/files/documents/2021-11/nams-work-plan_11_15_21_508-tagged.pdf) | EPA, 2021a
EPA Strategic Plan to Reduce the Use of Vertebrate Animals in Chemical Testing (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/strategic-plan-reduce-use-vertebrate-animals-chemical) | EPA, 2021b
Advancing New Alternative Methodologies at FDA (https://www.fda.gov/media/144891/download) | FDA, 2021a