# APPENDIX C ANALYTICAL METHOD ASSESSMENT

The information in Appendix C was derived from several references, including “Validation and Regulatory Acceptance of Toxicological Test Methods” (ICCVAM, 1997), “Bioanalytical Method Validation Guidance for Industry” (FDA, 2018), OECD GD 34 (OECD, 2005), and the OECD GIVIMP document (OECD, 2018). The information in Appendix C is intended to provide a general framework for method assessment. Some aspects may or may not be applicable to all methods.

## 1.0 Limits of Detection and Quantification

The limits of detection and quantification define the range of an analytical method. The analytical method is often tested either at the lower limit of quantification or at the limit of detection, whichever is more appropriate for the system. This process determines the lower end of the range of an analytical method by establishing the lowest quantity or concentration of an analyte that can be reliably detected (limit of detection) or quantified (lower limit of quantification) above the reagent blank or within the standard curve. The highest concentration on the standard curve determines the upper limit of quantification.

## 2.0 Identification of Interference

Method developers should document interfering substances, which can come from critical and non-critical components of the method, including any interference with the detected signal (e.g., fluorescence/absorbance, luciferase, enzymatic) of the method. Interference can also come from consumables, such as certain plastics in endocrine disruptor test methods as well as other reagents in the method. Potential interfering substances include, but are not limited to, endogenous matrix components, metabolites, decomposition products, and other xenobiotics. If the method is intended to quantify more than one analyte, all intended analytes should be tested to ensure that there is no interference. Blank samples are often used to test for interference.

## 3.0 Assessing Analytical Precision

It is helpful to include a description of the precision of the analytical method used and any other tests of precision, such as those assessing performance variability when different personnel use the proposed method, or when different instrumentation is used for the method, as well as participating in interlaboratory comparison studies when possible.

## 4.0 Stability of Materials

Stability as it relates to materials used in the NAM (e.g., test substances, testing apparatus, reagents, and analytes) refers to a material’s ability to produce similar and acceptable results over a period of time in a given environment. The stability of the NAM itself is discussed earlier (Appendix B, Section 3.0) with evaluation of control charts across time. The effects of sample collection, handling, and storage conditions should be evaluated. Materials that can be affected by stability issues should be given expiration dates appropriately. The stability of a test substance, reagents, and testing apparatus (e.g., plastic microplate) should be ensured to avoid interferences from degradation products and changes to the applied actual dose. Stability studies performed on any of the components should be included in reporting. The stability of any chemical mixtures or prepared samples being prepared before the day of the study should be evaluated for stability before use in development, validation, or qualification studies.

The chemical stability of a given mixture or matrix under specific conditions for given time intervals is assessed in several ways. Pre-study stability evaluations should cover the expected sample handling and storage conditions during the conduct of the study, including conditions at the test site, during shipment, and at all other secondary sites. The stability of an analyte in a particular mixture, matrix, and container system is relevant only to that mixture, matrix, and container system and should not be extrapolated to other systems. Stability testing should evaluate the stability of the analytes for long-term (frozen at the intended storage temperature) and short-term (bench top, room temperature) storage, and after freeze and thaw cycles and the analytical process. Conditions used in stability experiments should reflect situations likely to be encountered during actual sample handling and analysis. If, during sample analysis for a study, storage conditions changed and/or exceeded the sample storage conditions evaluated during technical characterization of the method, stability should be established under these new conditions. Independent stability studies should be conducted and cover any condition a critical reagent may encounter. Stability testing of a reagent or material should be considered for a variety of contexts, including during freeze-thaw cycles and use on the benchtop, in stock solutions, in processed samples, and over long-term studies.

## 5.0 Robustness Testing

Robustness is the ability of a method to be reproduced under different conditions or circumstances without the occurrence of unexpected differences in the obtained results. One aspect of a NAM’s robustness is the consistency of the control charting results across time as described in Appendix B, Section 3.0. Robustness testing is often used to detect changes in results from unintended variations in experimental reagents or protocols. Robustness testing is recommended for all aspects of test methods, and ranges for all parameters and measurements should be established whenever and wherever possible.

For example, an incubation time of 5 minutes was established as optimal for a study, but after robustness testing, data passed all quality control requirements at 5 minutes plus or minus 30 seconds. Therefore, the robustness-tested acceptable incubation time would be 5 minutes ± 30 seconds.

Some study parameters that should have an established acceptance range include:

- Incubation times
- Incubation temperatures
- pH
- Sources of reagents
- Cell densities (if applicable)
- Experimental conditions
- Analysis software

The design of the model will determine what experimental conditions will require acceptance ranges. For example, models with flowing media will need acceptance ranges for parameters related to flow. More complex models are more likely to have study parameters requiring control.

When applicable, results of robustness testing for critical and non-critical reagents should also be reported. Different suppliers (whenever practical) should be tested to determine if a reagent should be purchased from one supplier or if multiple suppliers can be used. This can also be helpful for avoiding supply chain disruptions or if a manufacturer stops making a specific product.

Instrumentational robustness testing should also be conducted whenever applicable. Cross-laboratory validation often involves different brands of instruments with different performance parameters and capabilities, which can add to the variability of the data or change parameters of the method performed.

## 6.0 Analysis of Recovery

Studies performing tests on extractions from a given matrix should perform recovery studies to verify the efficiency and reproducibility of the extraction method. Recovery studies are often performed by comparing the results of the extracted samples with those of spiked samples of a similar matrix and/or spiked blanks.

## 7.0 Technical Analysis of Applicability Domain

There should be adequate test method data for chemicals and/or products representative of those relevant to the specific COU for which the test is proposed. Documentation for the NAM, DA, or IATA should clearly describe the physicochemical properties of the applicability domain. This would include any limitation of the method, such as for chemicals of a specific molecular weight range, volatility, solubility, or stability.

While the applicability domain should be analytically evaluated during the initial development of an assay, additional data may become available through broader usage of the method. These data could reveal interferences that may need to be further addressed technically (Petersen et al., 2022a). If an assay is not evaluated for chemicals with certain physicochemical properties, there will be greater uncertainty regarding the assay performance for these chemicals both from analytical (e.g., whether there are biases that impact the assay performance) as well as potential concordance (e.g., whether the assay yields similar results as an in vivo assay) considerations. Therefore, it may also be valuable to assess the assay concordance across chemicals with different physico-chemical properties to increase confidence in the applicability of the assay with a broader range of chemicals.

## 8.0 Positive Control

At least one positive control should be part of the assay development. These controls can be used in conjunction with standard curves or as a single concentration for the positive control. The positive controls should be relevant to the endpoint of detection for the assay. The concentration of the positive control should lie within the detection window for the assay. Often, a positive control concentration is chosen to yield a response between 50% and 80% of the maximum detection range if only a single concentration is tested and data on the resolution of the maximum dose is available. A standard curve is often produced using the positive control for the system, with a standard curve defined as the relationship between assay response and known concentrations of the analyte. The standard curve should be reproducible over time. Standard curves should be prepared in the same vehicle or solvent as the intended test samples of the study. When the same mixture or matrix cannot be obtained, surrogate mixtures or matrixes can be used with proper documentation and justification.

## 9.0 Reference Standards for Instrument Calibration

When applicable, instruments should be calibrated using calibration standards and/or quality control samples. The source of the standard or quality control sample should be documented, including purity, stability, source, lot number, certificate of analysis, and expiration date. There are several types of standards such as U.S. Pharmacopeia compendial standards and commercially supplied materials obtained from a reputable commercial source with documented purity.

Ideally, the control standard for some instruments (e.g., mass spectrometers) should be identical to the analyte of interest in the assay. Often this is not possible, and an established chemical form of known purity can be used.

## 10.0 Setting Specifications

Specifications can be set for in-process control measurements based on intra-laboratory or interlaboratory test results. There are multiple approaches that can be used. For example, commonly used methods apply a 95% confidence interval to the in-process control measurements or use the mean ± two or three times the standard deviation value, but other statistical approaches are often used as well. Setting specifications involves balancing different objectives. It is important to have the specifications sufficiently stringent to exclude data indicating that the assay is not working as expected or that the data for an in-process control measurement is within a range where it could bias the test substance result. It is also important to not set the specifications so tightly that tests with test data in what would be considered a normal range have an overly high number of assay runs fail to meet the specifications.