# APPENDIX B QUALITY TOOLS

## 1.0 Flow Charts

In a flow chart, every step in a protocol is diagrammed (see Figure S1 for an example). This can be helpful in designing control measurements for the experiment by ensuring that each step is covered and tracked when feasible. It is possible for more than one control measurement to cover a single step, and conversely a control measurement may cover multiple steps. In addition, comparing control measurements among NAMs may reveal similar steps among different NAMs. For these steps, the sources of variability will also likely be similar.

Supplemental Figure 1 Flow chart describing the modified MTS (3-(4,5-dimethylthiazol-2-yl)-5-(3-carboxymethoxyphenyl)-2-(4-sulfophenyl)-2H-tetrazolium) protocol for an interlaboratory study. This figure is reprinted with permission from Elliott et al. (2017).

Supplemental Figure 1 shows a flow diagram; first five steps describe culturing of cells. Two parallel tracks then describe the treatment of cells using either serum or serum-free medium.

## 2.0 Cause-and-Effect Analysis

Cause-and-effect (C&E) analysis is a conceptual tool that can be used to identify possible key sources of variability and display them using C&E diagrams, sometimes known as fish-bone diagrams (see Figure S2 for an example). The process of developing these diagrams can include brainstorming and reviewing the literature on an assay. Each branch of the C&E diagram indicates a key source of expected variability. C&E diagrams can also support development of new NAMs, because shared branches of C&E diagrams (e.g., performing measurements using the same type of cytotoxicity assay) can be made more quickly, will likely require similar control measurements, and will likely have similar variability mitigation strategies. Analysis of C&E diagrams can help identify aspects of a method that may be challenging to standardize (e.g., an instrument challenging to calibrate or unstable assay reagents). C&E diagrams can help guide robustness testing and the selection of control measurements so that, ideally, the sources of variability in each branch and subbranch of the C&E diagram are analyzed.

Supplemental Figure 2 Cause-and-effect diagram of an MTS cytotoxicity assay designed for use with engineered nanomaterials. Reprinted with permission from Rösslein et al. (2015).

Supplemental Figure 2 shows a fish-bone diagram, with sources of variability grouped into six categories: cell maintenance, pipetting, instrument performance, toxic chemical positive control, assay protocol, and engineered nanomaterial handling and characterization.

## 3.0 Control Charts

Control measurements can be one-time preliminary experiments (e.g., to test for potential biases), periodic measurements performed at a predetermined frequency (e.g., evaluation of instrument performance and instrument calibration), and in-process control measurements made each time the assay is performed. For some assays that allow for a limited number of samples to be analyzed concurrently (e.g., an inhalation assay with exposure to aerosolized chemicals using a flowthrough exposure system), periodic measurements can be helpful. One-time preliminary experiments can be helpful to evaluate if a test substance may cause a bias, for example, if a nanoparticle may adsorb a key assay reagent. In-process control measurements can be used to measure key sources of variability each time the assay is performed. For example, one common in-process control measurement is the positive control. This control measurement can reveal if a maximal response (100 % effect) is reached and can also be used to demonstrate the sensitivity of the assay response to chemical concentrations that yield lower, more moderate responses. Key considerations for selecting a positive control have been described by Petersen et al. (2021). Additional common in-process control measurements are a control with no cells and no additional assay reagents and a control with cells and additional assay reagents added but without test substances. It may not be possible to include all potential in-process control measurements, and there may be tradeoffs in terms of what in-process control measurements to include.

Key sources of variability can be monitored across time and among experiments using control charts that display the mean values and variability of in-process control measurements (see Figure S3 for an example). This can be helpful to assess if there are systematic changes in the mean or variability values across time which suggest that something in the assay may have changed (e.g., instability of a reagent). Reviewing the check sheets can be helpful to identify why changes occurred.

Supplemental Figure 3 Control charting data for the electrophilic allergen screening assay fluorescence method for the negative incubator control: (A) mean and (B) coefficient of variation for all experiments depending on the date they were performed. In graph B, one value is an outlier for the coefficient of variation and outside of the specifications for this study (overall mean ± 3 times the average standard deviation value). Also, there is not a systematic trend with either the mean or coefficient of variation values across time. This figure has been modified and reprinted with permission from Petersen et al. (2022c) while the figure caption is modified and reprinted from Petersen et al. (2022b).

Supplemental figure 3 shows two plots, described in the following text.

## 4.0 Check Sheets

To record key metadata and fulfill requirements for GLP, check sheets can be used. If GLP is not used when a method is being developed, principles laid out in GLP such as recording key data using check sheets will be important if the NAMs are intended for regulatory submissions, when GLP-compliance may be required. Alternative relevant resources during assay development are the guidance document on GCCP 2.0 (Pamies et al., 2022) and GIVIMP (OECD, 2018) that are specific to cell-based work with additional quality management lists to ensure reproducibility and high-quality scientific data. Check sheets can also be useful for monitoring the in-process control measurements and supporting troubleshooting when issues arise. For example, they can be used to document changes in lot numbers for reagents and consumable supplies (e.g., pipettes and microwell plates). This can be valuable for troubleshooting if one specification is not met more frequently than other specifications. It is also possible for check sheets that include data calculators to evaluate if data from an assay run meets all the specifications and to perform statistical evaluations of the assay results. Electronic notebooks and laboratory information management systems may be used instead of written check sheets (with advantages such as ease of storage, transferability among laboratories, and searchability).

## 5.0 Scatterplots

Scatterplots can be used to assess if there is an interaction between different in-process control measurements or between those control measurements and test substance results (see Figure S4 for an example). The test substance results should be independent of the results for in-process control measurements within the range set by specifications.

Supplemental Figure 4 Correlation of cadmium sulfate (CdSO_4_) EC_50_ values determined using the MTS assay with mean optical density (OD) values of A549 cells not exposed to a test substance or the positive control.These data either show a lack of an interaction between the EC_50_ values (part A) or an interaction (part B) depending upon the range of mean OD values. The solid lines are linear regression fits. The slope in part B is statistically different from 0, indicating that the EC_50_ value is correlated with the OD values. Modified and reprinted with permission from Petersen et al. (2022b) and the figure caption is reprinted with permission from Petersen et al. (2022b).

Supplemental Figure 4A shows a scatter plot described in the following text. Supplemental Figure 4B shows a scatter plot described in the following text.