# APPENDIX A GLOSSARY

DISCLAIMER: This glossary is intended to support the use of terminology within this report. The meaning or use of a particular term may vary across regulatory agencies.

3Rs: Principles of humane experimental technique, specifically regarding the reduction (i.e., minimizing the number of animals used), replacement (i.e., use of a lower-order species or non-animal test), or refinement (i.e., minimizing the pain or distress that research animals might endure due to a particular technique) of the use of animals in research and chemical safety testing.
Accuracy: The closeness of agreement between a test method result and an accepted reference value.
Adverse outcome pathway (AOP): A structured representation of sequential events that occur at different levels of biological organization resulting in an adverse effect when an organism is exposed to a substance.
Applicability domain: The types of chemicals that can be tested using a method, or the types of chemicals for which the results produced by that method are considered acceptable.
Assay: The experimental system used. Often used interchangeably with “test” and “test method”.
Balanced accuracy: A statistical metric used to account for an imbalanced data set where one “class” appears much more than the other (e.g., higher number of negatives than positives). Balanced accuracy is calculated as the arithmetic mean of sensitivity and specificity.
Biological relevance: A measure of appropriateness for assessing the effects of a chemical within the taxa of interest.
Concordance: The closeness of agreement or consistency between two variables. Concordance may be used to qualitatively describe the biological relevance of a NAM compared with the reference animal test method and/or human reference data when available. Concordance may also be used to quantitatively describe the proportion of all chemicals tested that are correctly classified as positive or negative, and the term is often used interchangeably with “accuracy” in this context.
Context of use (COU): A clearly articulated description delineating the manner and purpose of use for a particular method, approach, or application.
Curated database/list: A structured set of well-characterized and reliable information that is carefully compiled and maintained.
Defined approach (DA): Consists of input data generated with a defined set of information sources and a fixed data interpretation procedure to derive a result that can either be used on its own or together with other information sources within an IATA to satisfy a specific regulatory need. A defined approach to testing and assessment can be used to support the hazard identification, hazard characterization, and/or safety assessment of chemicals (OECD, 2017).
Discordance: The proportion of all chemicals tested incorrectly classified as positive or negative.
Endpoint: The biological or chemical process, response, or effect assessed by a test method.
False negative: A substance incorrectly identified as negative by a test method relative to the specified reference data.
False positive: A substance incorrectly identified as positive by a test method relative to the specified reference data.
Fit-for-purpose: Matching the type and certainty of information provided by a NAM (or set of NAMs) with the type and certainty of information needed for a given decision (EPA, 2021a).
Good Cell Culture Practice (GCCP): A set of principles developed for practical use in the laboratory to ensure the reproducibility of in vitro (cell-based) work and enhance quality of scientific data (Pamies et al., 2022).
Good In Vitro Method Practices (GIVIMP): A comprehensive framework described in the OECD Guidance Document on Good In Vitro Method Practices (OECD, 2018) that provides recommendations for the development, validation, regulatory acceptance or qualification, and use of in vitro methods.
Good Laboratory Practices (GLP): Regulations promulgated by authorities such as the U.S. EPA, U.S. FDA, and OECD that describe record keeping and quality assurance procedures for laboratory records that will be the basis for data submissions to national regulatory agencies.
Hazard: The potential for an adverse or harmful health or ecological effect.
Hazard classification: Assignment of a chemical or product hazard to a category based on the results of a standard test method for a specific toxicity endpoint; most commonly used for labeling purposes.
Hazard identification: That part of risk assessment associated with the determination of whether exposure to a particular substance is or might be associated with adverse health or ecological effects.
Integrated Approach to Testing and Assessment (IATA): An approach based on multiple information sources used for the hazard identification, hazard characterization and/or safety assessment of chemicals (OECD, 2017).
Interlaboratory reproducibility: A measure of whether different qualified laboratories using the same protocol and test chemicals can produce qualitatively and quantitatively similar results. Interlaboratory reproducibility is determined during the prevalidation and validation processes and indicates the extent to which a test method can be transferred successfully among laboratories.
Mechanistic relevance: A measure of appropriateness for assessing the biochemical process or pathway by which a chemical may exert an effect.
Negative predictivity: The proportion of correct negative responses relative to the defined reference data among substances testing negative by a test method. It is one indicator of test method accuracy. Negative predictivity is a function of the specificity of the test method and the prevalence of negatives among the substances tested.
New approach methodology (NAM): A broadly descriptive reference to any technology, methodology, approach, or combination thereof that can be used to provide information on chemical hazard and risk assessment and that supports replacement, reduction, or refinement of animal use (3Rs).
Performance: The accuracy and reliability characteristics of a test method (see “accuracy”, “reliability”).
Performance standards: Standards, based on a validated test method, that provide a basis for evaluating the comparability of a proposed test method that is mechanistically and functionally similar. Included are (1) essential test method components; (2) a list of reference chemicals selected from among the chemicals used to demonstrate the acceptable performance of the validated test method; and (3) the comparable levels of accuracy and reliability, based on what was obtained for the validated test method, that the proposed test method should demonstrate when evaluated using the minimum list of reference chemicals.
Positive predictivity: The proportion of correct positive responses among substances testing positive relative to the defined reference data by a test method. It is one indicator of test method accuracy. Positive predictivity is a function of the sensitivity of the test method and the prevalence of positives among the substances tested.
Potency: A measure of the relative biological or chemical activity of a substance. The potency of a single substance can differ for different biological or biochemical effects.
Precision: The closeness of individual measurements of an analyte after multiple analyses, often of a single sample. Precision is often expressed as the coefficient of variation.
Protocol: The precise step-by-step description of a test method, including the listing of all necessary reagents and all criteria and procedures for generating and evaluating test data.
Qualification: A conclusion that the results of an assessment using a validated model or assay can be relied upon to have a specific interpretation and application in product development and regulatory decision-making.
Quality control: A set of activities or samples used to verify that the quality of the product or method is maintained as intended.
Reference compounds: Chemicals selected for use during the research, development, or evaluation of a proposed test method because their response in the reference test method or the species of interest is known (see “reference test method”).
Reference test method: The accepted test method used for regulatory purposes to evaluate the potential of a test substance to be hazardous to the species of interest.
Reliability: A measure of the degree to which a test method can be performed reproducibly within and among laboratories over time. It is assessed by calculating intra- and interlaboratory reproducibility and intra-laboratory repeatability.
Repeatability: The consistency of test results obtained when the procedure is performed on the same substance under identical conditions within a given time period; “…the closeness of the agreement between independent results obtained with the same method on the identical subject(s) (or object or test material), under the same conditions” (Slezák and Waczulíková, 2011).
Reproducibility: The consistency of individual test results obtained using the same test protocol and test samples; “…the closeness of the agreement between independent results obtained with the same method on the identical subject(s) (or object, or test material), but under different conditions (different observers, laboratories etc.)” (Slezák and Waczulíková, 2011).
Recovery: A quantitative method of verifying the efficiency and reproducibility of an extraction method by comparing the results of the extracted samples with those of spiked samples of a similar matrix and/or spiked blanks.
Risk assessment: Evaluation of the potential adverse health and environmental effects to a target species from exposures to exogenous agents.
Robustness: The ability of a method to be reproduced under different conditions or circumstances, without the occurrence of unexpected differences in the obtained results.
Sensitivity: The proportion of all positive chemicals that are classified correctly as positive in a test method. Sensitivity may also be defined in the context of detection limits as the lowest analyte concentration that can be measured with acceptable accuracy and/or precision.
Specificity: The proportion of all negative chemicals that are classified correctly as negative in a test method. It is a measure of test method accuracy. This word is also used to describe the ability of an analytical method to detect a specific analyte.
Stability: The ability of a test material (e.g., test substance, testing apparatus, reagent, or analyte) to produce similar and acceptable results over a period of time in a given environment.
Standard curve: A quantitative method of plotting assay data to determine the concentration of a substance in an unknown sample by comparing the unknown to a standard sample of known concentration (often using the positive control material).
Standard operating procedures (SOPs): Formal, written procedures that describe how specific laboratory operations are to be performed. These are required by GLP guidelines.
Target organ: The organ for which information on the potential toxicity of a chemical is sought.
Target species: The species for which information on the potential toxicity of a chemical is sought.
Test: The experimental system used; used interchangeably with “test method” and “assay”.
Test method: A process or procedure used to obtain information on the characteristics of a substance or agent. Toxicological test methods generate information regarding the ability of a substance or agent to produce a specified biological effect under specified conditions. Used interchangeably with “test” and “assay”. See also “validated test method” and “reference test method”.
Test method developer: The organization or individual that initially devises a test method and ensures its reproducibility and suitability for the intended use.
Test method sponsor: The organization or individual that puts forward a test method submission for consideration; may also be the same organization or individual as the test method developer.
Test method submission: Compendium of supporting documentation for a test method that is proposed for a regulatory or other defined application. A test method submission generally includes records of validation studies that have been completed to characterize the usefulness and limitations of the test method for a specific proposed regulatory testing requirement or application as well as other adequate documentation of the scientific validity prepared in accordance with test method submission guidelines.
Transferability: The ability of a test method or procedure to be accurately and reliably performed in different, competent laboratories. See also “interlaboratory reproducibility”.
Validated test method: An accepted test method for which validation studies have been completed to determine the accuracy, reliability, and relevance of this method for a specific proposed use.
Validation: The process by which the accuracy, reliability, and relevance of a procedure are established for a specific purpose. Validation for one specific purpose does not imply validation for other specific purposes. Further qualification may be needed for a particular context of use.