# Abbreviations and Acronyms

3Rs: replacement, reduction, or refinement of animal use
AOP: adverse outcome pathway
C&E: cause-and-effect
COU: context of use
CPSC: U.S. Consumer Product Safety Commission
DA: defined approach
EPA: U.S. Environmental Protection Agency
EURL ECVAM: European Union Reference Laboratory for the Validation of Alternative Methods
FDA: U.S. Food and Drug Administration
GD: guidance document
GHS: Globally Harmonized System for Classification and Labelling of Chemicals
GIVIMP: Guidance Document on Good In Vitro Method Practices
GLP: Good Laboratory Practices
IATA: Integrated Approaches to Testing and Assessment
ICATM: International Cooperation on Alternative Test Methods
ICCVAM: Interagency Coordinating Committee on the Validation of Alternative Methods
ICH: International Council for Harmonization of Technical Requirements for Pharmaceuticals for Human Use
IQ/OQ/PQ: Installation Quality/Operation Quality/Performance Quality
JaCVAM: Japanese Center for the Validation of Alternatives Methods
MTS: (3-(4,5-dimethylthiazol-2-yl)-5-(3-carboxymethoxyphenyl)-2-(4-sulfophenyl)-2H-tetrazolium)
NAMs: new approach methodologies
NCATS: National Center for Advancing Translational Sciences
NICEATM: National Toxicology Program Interagency Center for the Evaluation of Alternative Toxicological Methods
NIEHS: National Institute of Environmental Health Sciences
OD: optical density
OECD: Organisation for Economic Co-operation and Development
SOP: standard operating procedure
TG: test guideline
Tox21: Toxicology in the 21st Century
TSAR: Tracking System for Alternative methods towards Regulatory acceptance