# X References

Chang X, Tan YM, Allen DG, Bell S, Brown PC, Browning L, Ceger P, Gearhart J, Hakkinen PJ, Kabadi SV, Kleinstreuer NC, Lumen A, Matheson J, Paini A, Pangburn HA, Petersen EJ, Reinke EN, Ribeiro AJS, Sipes N, Sweeney LM, Wambaugh JF, Wange R, Wetmore BA, Mumtaz M. (2022). IVIVE: Facilitating the Use of In Vitro Toxicity Data in Risk Assessment and Decision Making. Toxics. 2022 May 1;10(5):232. Doi: 10.3390/toxics10050232. PMID: 35622645; PMCID: PMC9143724.35622645
EPA, (2010). TSCA New Chemicals Program (NCP) Chemical Categories. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. [Online] August 2010. https://www.epa.gov/system/files/documents/2024-02/ncp_chemical_categories.pdf
EPA, (2012). Guidance for Waiving or Bridging of Mammalian Acute Toxicity Tests for Pesticides and Pesticide Products (Acute Oral, Acute Dermal, Acute Inhalation, Primary Eye, Primary Dermal, and Dermal Sensitization). U.S. Environmental Protection Agency, Office of Pesticide Programs. [Online] March 1, 2012. https://www.epa.gov/sites/default/files/documents/acute-data-waiver-guidance.pdf
EPA, (2013a). Guiding Principles for Data Requirements. [Online] May 31, 2013. https://www.epa.gov/pesticide-registration/guiding-principles-data-requirements
EPA, (2013b). Part 158 Toxicology Data Requirements: Guidance for Neurotoxicity Battery, Subchronic Inhalation, Subchronic Dermal and Immunotoxicity Studies. [Online] May 01, 2013. https://www.epa.gov/pesticide-registration/determining-toxicology-data-requirements
EPA, (2015). Use of an Alternate Testing Framework for Classification of Eye Irritation Potential of EPA Pesticide Products. [Online] March 02, 2015. https://www.epa.gov/sites/default/files/2015-05/documents/eye_policy2015update.pdf.
EPA, (2016a). Process for Evaluating and Implementing Alternative Approaches to Traditional In Vivo Acute Toxicity Studies for FIFRA Regulatory Use. [Online] February 04, 2016. https://www.epa.gov/pesticide-science-and-assessing-pesticide-risks/process-establishing-implementing-alternative
EPA, (2016b). Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Formulations and Supporting Retrospective Analysis. [Online] November 9, 2016. https://www.epa.gov/sites/default/files/2016-11/documents/acute-dermal-toxicity-pesticide-formulations_0.pdf
EPA, (2018a). Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program. June 22, 2018. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention, Washington, DC. EPA-740-R1–8004. https://www.regulations.gov/document/EPA-HQ-OPPT-2017-0559-0906
EPA, (2018b). Interim Science Policy: Use of Alternative Approaches for Skin Sensitization as a Replacement for Laboratory Animal Testing. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. April 4, 2018 https://www.regulations.gov/document/EPA-HQ-OPP-2016-0093-0090
EPA, (2018c). Points to Consider When Preparing TSCA New Chemical Notification. June 2018. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics, Washington, DC. https://www.regulations.gov/document/EPA-HQ-OPPT-2022-0902-0026
EPA, (2019). OCSPP Harmonized Test Guidelines Master List. Available at: https://www.epa.gov/test-guidelines-pesticides-and-toxic-substances/master-list-test-guidelines-pesticides-and-toxic
EPA, (2020a). Hazard Characterization of Isothiazolinones in Support of FIFRA Registration Review. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. April 6, 2020. https://www.regulations.gov/document/EPA-HQ-OPP-2013-0605-0051
EPA, (2020b). Use of New Approach Methodologies to Derive Extrapolation Factors and Evaluate Developmental Neurotoxicity for Human Health Risk Assessment. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention. July 2020. https://www.regulations.gov/document/EPA-HQ-OPP-2020-0263-0006
EPA, (2020c). Fish Bioconcentration Data Requirement: Guidance for Selection of Number of Treatment Concentrations. EPA-705-G-2020–3708 [Online] July 15, 2020. https://www.epa.gov/sites/default/files/2020-07/documents/bcf-study-july-15-2020.pdf
EPA, (2020d). Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Technical Chemicals and Supporting Retrospective Analysis. [Online] December 31, 2020. https://www.epa.gov/sites/default/files/2021-01/documents/guidance-for-waiving-acute-dermal-toxicity.pdf
EPA, (2020e). Final Guidance for Waiving Sub-Acute Avian Dietary Tests for Pesticide Registration and Supporting Retrospective Analysis. [Online] February 2020. https://www.epa.gov/sites/default/files/2020-02/documents/final-waiver-guidance-avian-sub-acute-dietary.pdf
EPA, (2021a). New Approach Methods Work Plan (v2). U.S. Environmental Protection Agency. EPA/600/X-21/209. Available at: https://www.epa.gov/system/files/documents/2021-11/nams-work-plan_11_15_... (https://www.epa.gov/system/files/documents/2021-11/nams-work-plan_11_15_21_508-tagged.pdf)
EPA, (2021b). List of Alternative Test Methods and Strategies (or New Approach Methodologies [NAMs]). [Online] Second update, February, 4, 2021. https://www.epa.gov/sites/default/files/2021-02/documents/nams_list_second_update_2-4-21_final.pdf
EPA, (2021c). Chlorothalonil: Revised Human Health Draft Risk Assessment for Registration Review. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention April 9, 2021. https://www.regulations.gov/document/EPA-HQ-OPP-2011-0840-0080
EPA, (2021d). OncoLogic™Version 9.0 User Guide. January 2021. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics, Washington, DC. https://www.epa.gov/tsca-screening-tools/oncologictm-version-90-user-guide
EPA, (2021e). National PFAS Testing Strategy: Identification of Candidate Per- and Poly-fluoroalkyl Substances (PFAS) for Testing. [Online] October 2021. [Online] https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/national-pfas-testing-strategy
EPA, (2021f). A Proof-of-Concept Case Study Integrating Publicly Available Information to Screen Candidates for Chemical Pre-Prioritization under TSCA. June 2021. U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention and Office of Research and Development, Washington, DC. EPA/600/R-21–106
EPA, (2022a). Chemical Safety for Sustainability Strategic Research Action Plan Fiscal Years 2023–2026. [Online] October 2022. U.S. Environmental Protection Agency, Office of Research and Development, Washington, DC. EPA/600/R-22–238. https://www.epa.gov/system/files/documents/2022-10/CSS%20FY23-26%20StRAP_EPA-ORD_October%202022_508.pdf
EPA, (2022b). Methodology Document for the ECOlogical Structure-Activity Relationship Model (ECOSAR). Version 2.2. U.S Environmental Protection Agency, Office of Pollution Prevention and Toxics, Washington DC. February 2022. [Online] https://www.epa.gov/system/files/documents/2022-03/methodology-document-v.2.2.pdf
EPA, (2022c). Drinking Water Contaminant Candidate List 5—Final. Federal Register. Vol. 87, No. 218, November 14, 2022. Docket ID No. EPA-HQ-OW-2018–0594
EPA, (2022d). Availability of New Approach Methodologies (NAMs) in the Endocrine Disruptor Screening Program (EDSP). December 12, 2022. https://www.regulations.gov/document/EPA-HQ-OPP-2021-0756-0002
EPA, (2023a). Status of Endocrine Disruptor Screening Program (EDSP) List 1 Screening Conclusions. October 2023. U.S. Environmental Protection Agency. https://www.regulations.gov/document/EPA-HQ-OPP-2023-0474-0001
EPA, (2023b). Guidance on Use of Weight of Evidence When Evaluating The Human Carcinogenic Potential of Pesticides. U.S. Environmental Protection Agency, Office of Pesticide Programs, Washington, DC. June 2023. [Online] https://www.epa.gov/system/files/documents/2023-06/2023%20CARC%20WoE%20Guidance.pdf
EPA, (2024). Framework for Estimating Noncancer Health Risks Associated with Mixtures of Per- and Polyfluoroalkyl Substances (PFAS). EPA-815-R-24–003. U.S. Environmental Protection Agency, Office of Water and Office of Research and Development, Washington, DC.
NAFTA, (2012). Quantitative Structure Activity Relationship [(Q)SAR] Guidance Document. North American Free Trade Agreement Technical Working Group on Pesticides November, 2012.
OECD, (2014). Guidance Document on the Validation of (Quantitative) Structure-Activity Relationship [(Q)SAR] Models, OECD Series on Testing and Assessment, No. 69, OECD Publishing, Paris, 10.1787/9789264085442-en.
OECD, (2021). Guidance Document on the Characterisation, Validation and Reporting of PBK Models for Regulatory Purposes, OECD Series on Testing and Assessment, No. 331, OECD Publishing, Paris. 3 February 2021 [online] https://one.oecd.org/document/ENV/CBC/MONO(2021)1/en/pdf
OECD, (2023). Initial Recommendations on Evaluation of Data from the Developmental Neurotoxicity (DNT) In-Vitro Testing Battery. OECD Series on Testing and Assessment, No. 377. [Online] 3 November 2023. https://one.oecd.org/document/ENV/CBC/MONO(2023)13/en/pdf
Thomas, R. S., Bahadori, T., Buckley, T. J., Cowden, J., Deisenroth, C., Dionisio, K. L., Frithsen, J. B., Grulke, C. M., Gwinn, M. R., Harrill, J. A., Higuchi, M., Houck, K. A., Hughes, M. F., Hunter, E. S., Isaacs, K. K., Judson, R. S., Knudsen, T. B., Lambert, J. C., Linnenbrink, M., Martin, T. M., … Williams, A. J. (2019). The Next Generation Blueprint of Computational Toxicology at the U.S. Environmental Protection Agency. Toxicological sciences: an official journal of the Society of Toxicology, 169(2), 317–332. 10.1093/toxsci/kfz058 30835285
Woo Y.T., Lai D.Y., Argus M.F., Arcos J.C. (1995). Development of structure-activity relationship rules for predicting carcinogenic potential of chemicals. Toxicol Lett. 1995 Sep;79(1–3):219–28. 10.1016/0378-4274(95)03373-S 7570659