# VII Conclusion

For EPA to fulfill its mandate to protect human health and the environment, the Agency continues to rely on human health and environmental effects data derived from toxicity testing in vertebrate animals. This is expected to continue until the issues identified as barriers to the use of NAMs are addressed. This review of the Agency’s regulatory landscape indicates the environmental laws providing the Agency’s authority are written broadly in most cases and the statutes do not generally preclude the use of scientific information or data from NAMs. For EPA to fulfill its mission to protect human health and the environment, the Agency must make decisions using information of high scientific quality and rigor, developed with scientifically sound methodologies, and subjected to peer-review. These principles apply to vertebrate animal testing and NAMs. Thus, the Agency will continue to identify the decision contexts where available NAMs are demonstrated to be the best available science.

Across all of EPA’s program offices, rules have been promulgated that inform the testing requirements for a range of regulatory decisions. A theme across these regulations is that a minimum set of vertebrate animal testing is usually required for decision-making. Therefore, each program office will need to identify the regulations that require revisions to incorporate data from NAMs when feasible and scientifically justified.

The survey of the Agency’s activities for incorporating NAMs detailed in Section V demonstrates that in cases where NAMs were utilized for regulatory decisions, the contexts were well defined, the alternative method was fit for its intended purpose, and the NAMs’ advantages and limitations were transparently evaluated. The activities outlined in the Agency’s NAMs Work Plan, such as case studies, trainings, and leveraging robust peer review processes, are critical to building confidence for regulators, the regulatory community, and affected stakeholders toward successful implementation of NAMs. The Agency will continue efforts to implement the NAMs Work Plan and conduct research programs toward innovation in NAMs development and application toward regulatory decision-making.