# VI Barriers to Implementation and Use of NAMs

The incorporation of new scientific approaches into regulatory decision-making has been shown to be an iterative process, in which several statutory and regulatory barriers arise. Although the majority of EPA’s statutory mandates do not specify the types of testing the Agency must require, language across statutes generally indicates that the scientific information considered should be of high quality, based on scientifically sound methodologies, and subjected to peer-review. In general, NAMs are developed to provide relevant information for a specific purpose or decision. Thus, the Agency must evaluate data from NAMs to determine its scientific reliability and relevance for risk-based decision-making to protect human health and the environment.

Due to the diverse statutes the Agency executes, the specific purpose or context of use of NAMs will vary accordingly. For instance, the 2016 amendments to TSCA directed the Agency to reduce or replace vertebrate animal testing where data from NAMs are found to meet or exceed the relevance and reliability of information provided by traditional in vivo methodologies. Since this statutory requirement is unique to TSCA, OPPT’s inclusion of NAMs data to evaluate new and existing industrial chemicals may outpace the rate of NAMs incorporated for other statutory activities.

The Agency has promulgated rules to fulfill the mandates of the major environmental statutes to protect human health and the environment. There are multiple regulations that explicitly require vertebrate animal testing for hazard assessment as detailed in Section III Regulatory Requirements for Vertebrate Animal Testing. For example, the CAA and associated regulations do not explicitly prohibit the use of NAMs; however, as the regulations are currently written, NAMs would not be able to replace all the vertebrate testing written into the regulations. Because of the current regulatory requirement for vertebrate toxicity testing under the Fuel and Fuel Additive Registration, and SNAP Program, new rulemaking would be required to incorporate NAMs that could replace specific tests that are currently required under the rule. Also, the validation and quantification of NAMs data is crucial to support risk-based regulatory decision making under the CAA. Similarly, the NPDES regulations promulgated in accordance with the CWA generally require that sampling conducted to complete permit applications and comply with permit monitoring requirements use test methods approved under EPA 40 CFR Part 136. The approved test methods for WET currently are based on vertebrate and invertebrate testing.

Lastly, OCSPP’s regulatory requirements, 40 CFR Part 158 and 40 CFR Part 797–799 (detailed in Appendix A; Table 2), prescribe test methods utilizing vertebrate animals to predict the human health and environmental hazard potential of a chemical substance. The regulations at 40 CFR Part 158 do allow for flexibility in the type of scientific information required in certain circumstances; however, for some of the complex toxicity endpoints, such as repeat dose toxicity, developmental toxicity, or reproductive toxicity, NAMs are not yet available to replace traditional toxicity tests. While some NAMs gained acceptance by international bodies several years ago, their utilization in Agency decision-making is relatively new in comparison. Further, the developing science and technology supporting advancements in NAMs is an evolving field. In contrast, the rulemaking process is time and resource intensive. This poses a challenge for the Agency to keep pace with the latest scientific advancements and revise regulations accordingly.

In several contexts outlined in Section V, data from NAMs may be incorporated in Agency decisions without initiating a new rulemaking due to the existing flexibility provided in the regulations. In contrast, several regulations may require revisions to utilize NAMs for decision-making. Since the regulatory activities across the Agency vary, new rulemaking to incorporate NAMs for decision-making may not follow a uniform approach. These differences in regulatory frameworks may lead to discrepancies in the application of NAMs across program offices. This presents an additional challenge for the Agency to communicate to stakeholders the relevance of NAMs in certain decision contexts and not others.