# V The Use of NAMs in Decision-Making

At this time, the Agency has relied on NAMs for multiple decision contexts in both OCSPP and Office of Water (OW). The application examples are briefly summarized below.

## i List of Alternative Test Methods and Strategies

TSCA Section 4(h)(2)(C) requires EPA to develop “a list, which the Administrator shall update on a regular basis, of particular alternative test methods or strategies the Administrator has identified that do not require new vertebrate animal testing and are scientifically reliable, relevant, and capable of providing information of equivalent or better scientific reliability and quality to that which would be obtained from vertebrate animal testing.” The TSCA NAMs List includes computational tools to identify analogs for read-across, structure-activity relationships (SARs), quantitative structure-activity relationships (QSARs), OECD test guidelines for effects on human health and biotic systems, and OCSPP science policy documents that are utilized for risk-based decision-making (EPA 2021b). Further, OPPT relies on NAMs developed by the EPA’s Center for Computational Toxicology and Exposure (CCTE) in ORD such as the CompTox Chemicals Dashboard. The methodologies currently included on the list have been evaluated and meet the criteria for scientific relevance and reliability as outlined in the TSCA Strategic Plan (EPA 2018a).

## ii Hazard Identification

OCSPP has collaborated with other federal agencies and external stakeholders on several projects to utilize in vitro assays to assess a substance’s potential to cause eye irritation and dermal sensitization. In 2015, the Agency released a guidance document entitled “Alternative Testing Framework for Classification of Eye Irritation Potential of Pesticides,” which describes a framework for assessing eye irritation potential of pesticide products using in vitro assays (EPA 2015). The framework is applicable to antimicrobial products and other pesticides on a case-by-case basis. Additionally, the interim science policy “Use of Alternative Approaches for Skin Sensitization” has been adopted by both OPP and OPPT (EPA 2018b). This draft policy document describes two approaches utilizing in vitro and in chemico test methods to identify skin sensitization.

## iii Dose-Response Assessment - Points of Departure

OPP has used NAMs in the dose-response assessment for a substance on a case-by-case basis. For example, several isothiazolinones were tested using in vitro and in chemico assays to determine concentrations of the chemicals that can cause induction of skin sensitization. These NAMs were utilized in the risk assessment for the isothiazolinones and are included in the Agency’s science policy document mentioned previously (EPA 2018b, EPA 2020a). In addition, OPP has collaborated with external stakeholders to develop an inhalation testing strategy that utilized data from an in vitro assay to derive an inhalation point of departure and in silico (computer-based) models to calculate a Human Equivalent Concentration (HEC) for the risk assessment of a respiratory contact irritant, chlorothalonil (EPA 2021c). These integrated methods demonstrated the importance of NAMs development that are fit-for-purpose and have the potential for providing human biological relevance for a risk determination.

## iv Mode of Action

OPPT has a long-standing history of utilizing predictive models (in silico NAMs) to assess health effects of new, industrial chemicals and incorporate these data in WoE approaches to inform prioritization activities, hazard identification, and risk assessments. In collaboration with the developer, LogiChem, Inc, OPPT publicly released the OncoLogic™ model, an expert system capable of predicting the carcinogenicity of a chemical when cancer bioassay data on the substance are not available. The model uses SAR analysis for 52 classes of organic chemicals, fibers, metals, and polymers. The model also incorporates information on a substance’s physical/chemical properties, stability, mode of action, and potential exposure to provide users with a prediction and scientific justification of cancer concern (Woo 1995; EPA 2021d).

In vitro assays are routinely used in OPP as part of the required battery of genotoxicity studies to identify chemicals with a potential for mutagenicity. In addition, OPP often utilizes in vitro assays and in silico models to inform early key events in the mode of action (MOA) for tumors and other non-neoplastic toxicities. The Cancer Assessment Review Committee within the Health Effects Division of OPP published guidelines detailing the data considerations and weight-of-evidence (WoE) analysis in the assessment of the carcinogenic potential of pesticides (EPA 2023b).

## v Pharmacokinetics

Programs across EPA use physiologically-based and conventional pharmacokinetic (PBPK and PK) modeling to characterize the quantitative relationship between external exposures and internal doses, such as blood or target tissue concentrations as well as extrapolate from media concentrations to administered doses. Both conventional PK and PBPK modeling are recognized as scientifically sound and robust tools. The PK and PBPK models can be parameterized with data derived from in vitro and in silico methods using in vitro to in vivo (IVIVE) extrapolation methods. PK and PBPK models have been used to interpret human biomonitoring data, animal dose-response data, and in vitro dose-response data. Additionally, OPP has used PBPK models to inform waiving animal studies or optimizing animal study design. EPA also led the development of the 2021 OECD guidance document (OECD 2021), which aims to provide insights on developing and evaluating PK and PBPK models parameterized with data derived from in vitro and in silico methods.

## vi Chemical Categories and Read-Across

Read-across is a NAM that is useful to address data gaps for a chemical across a variety of decision contexts. Similar chemicals or chemical categories are identified based on SARs and a prediction for an endpoint is determined for the target chemical. OPPT pioneered the development and use of analog identification as part of the risk assessment process of new chemicals under TSCA. This effort was largely driven by a paucity of data submitted with submissions and the short mandatory timeframe for decisions to be made (e.g., 90 days under Section 5 TSCA). OPPT also developed the TSCA New Chemicals Program (NCP) Chemical Categories to assist in the review of new chemicals with limited information (EPA 2010). The use of analog identification and chemical category development are tools to anchor the use of read-across for hazard and risk assessment. Similarly, OPP uses data on structurally similar chemicals to inform hazard characterization. For example, OPP’s Hazard and Science Policy Council (HASPOC), uses a weight-of-evidence approach to determine data needs in the risk assessment of pesticides. Data on structurally similar chemicals are incorporated into these evaluations to require additional toxicological testing or to waive testing requirements.

The “Points to Consider for TSCA New Chemical Notification” guidance document provides information for submitters of Section 5 new chemical notifications (EPA 2018c). The guidance describes the New Chemical Division’s process for assessing human health hazard, fate, environmental hazard, and exposure. This includes steps assessors take to identify relevant analogs with experimental data to further inform the hazard characterization where data on the new chemical substance are not available. The tools and models employed in this process are listed on the TSCA NAMs List (EPA 2021b).

EPA’s National Testing Strategy outlines a strategic approach to per-and-polyfluoroalkyl substances (PFAS) toxicity testing. Under the strategy, EPA has broken the large class of PFAS into smaller categories based on similar features and has identified PFAS categories with little or no available toxicity data (EPA 2021e). EPA can then identify a representative PFAS from data-poor categories for toxicity testing, which follows a tiered testing approach. The tiered testing approach uses results from in vitro assays in Tier 1 to inform the types of in vivo toxicity testing that may be needed in Tier 2 or Tier 3 tests.

## vii Predicting Ecological Effects

OPPT has consistently relied in silico NAMs to evaluate the hazard, exposure, and environmental fate properties on new chemical substances and mixtures where experimental data are not available. Several in silico NAMs have been developed by EPA offices and external bodies such as the OECD (i.e., OECD (Q)SAR Toolbox) (OECD 2014). These tools may be used to predict the physical/chemical properties, human health and ecological toxicity, and environmental fate of substances which may be used to support regulatory decision-making. The Ecological Structure Activity Relationships Class Program (ECOSAR), developed by OPPT and ORD, estimates a chemical’s acute and chronic toxicity to aquatic organisms by using a library of class-based QSARs. OPPT’s New Chemicals Program employs ECOSAR to predict the toxicity profile of freshwater fish, invertebrates and aquatic plants and can assign a new chemical to one of 111 chemical classes (EPA 2022b). Additionally, the TSCA NAMs List includes other databases and tools used to estimate environmental fate and potential exposures for chemicals evaluated under TSCA.

EPA is actively pursuing the incorporation of NAMs into the derivation of aquatic life benchmarks and criteria, with current investigations focusing on applications PFAS. EPA typically develops aquatic life criteria using laboratory data for surrogate aquatic taxa, but sometimes data are limited or unavailable, and NAMs can help fill data gaps. EPA is exploring the use of NAMs to derive aquatic life benchmarks/criteria for data-limited chemicals.

## viii Chemical Prioritization and Chemical Screening

The draft document “Availability of New Approach Methodologies (NAMs) in the Endocrine Disruptor Screening Program (EDSP)” describes the high-throughput in vitro assays and in silico models the Agency determined may be used as an alternative to certain EDSP Tier 1 screening assays (EPA 2022d). The estrogen receptor pathway model and the androgen receptor pathway model have been validated and data from these NAMs will be considered for specific chemicals. The draft document also describes other NAMs that may be used for priority setting and as other scientifically relevant information in weight of evidence evaluations. Recently, data from the ER and AR pathway models were used to support a prioritization strategy for conventional pesticides under EDSP (EPA 2023a).

EPA’s ORD, in collaboration with international bodies, has developed a battery of NAMs to evaluate the developmental neurotoxicity (DNT) potential of specific chemicals. The DNT NAM battery is comprised of multiple in vitro assays that measure key neurodevelopmental processes. In 2020, a case study on organophosphate (OP) pesticides was presented to the FIFRA Scientific Advisory Panel (SAP) (EPA 2020b). Further, the OECD published a guidance document which describes the process to incorporate data from the DNT NAM battery to support regulatory decision-making (OECD 2023). As OPP reevaluates the DNT potential of individual OP pesticides, future risk assessments will include data from these in vitro assays in conjunction with other lines of evidence in a WoE evaluation.

EPA’s OW also uses NAMs to prioritize chemicals found in drinking water and biosolids. Under the fifth Contaminant Candidate List cycle (CCL 5), EPA’s OW incorporated NAMs data for the first time in order to identify chemicals of interest and prioritize chemicals in drinking water that may require regulation under SDWA (EPA 2022c). For example, EPA used data collected under the ToxCast program (i.e., the percentage of active assays) as part of the screening points system used to prioritize chemical contaminants for the CCL 5. To prioritize chemicals found in biosolids, EPA is using the Public Information Curation and Synthesis (PICS) approach, which integrates publicly available hazard, exposure, persistence, and bioaccumulation information for chemical substances (EPA 2021f). The PICS approach synthesizes information from traditional methods and NAMs to understand the overall degree of potential concern related to human health and the environment.

## ix Assessing Chemical Mixtures

A significant challenge in evaluating water contaminants is the lack of hazard and dose-response data suitable for human health risk assessment for the large majority of chemicals in commerce. EPA’s OW and ORD collaborated to develop a framework for assessing noncancer health risks associated with PFAS mixtures in environmental media for public comment (EPA, 2024). The approach allows for flexible integration of information derived from formal noncancer health assessments [e.g., reference doses (RfDs) from federal, state, international sources], available human epidemiological and/or experimental animal hazard and dose-response data (that have not yet been formally evaluated in an assessment product), and information from NAMs (e.g., in vitro assays, in silico platforms). The framework presents three approaches including the hazard index (general hazard index and target-organ specific hazard index), relative potency factors, and a mixture benchmark dose (BMD) approach. Each approach is illustrated using a hypothetical mixture of PFAS with component chemicals ranging from data rich (e.g., peer reviewed final RfD available) to data poor (e.g., only NAM/in vitro data available).