# IV Research to Support the Regulatory Use of NAMs

EPA conducts research to provide solutions needed to meet today’s most complex environmental and human health challenges. Providing the scientific bases for the adoption and regulatory use of NAMs is one such research effort. The Agency is actively working to develop the science to support reducing, refining, and replacing vertebrate animal testing, as described in EPA’s NAMs Work Plan. Research efforts to support the adoption and use of NAMs in general fall under two areas highlighted in the NAMs Work Plan: A) Establish scientific confidence in NAMs and demonstrate application to regulatory decisions; and B) Develop NAMs to address scientific challenges and fill important information gaps. ORD, in partnership with the Agency’s regulatory programs and offices, conducts research programs and case studies to advance the development and use of NAMs. These efforts are augmented via partnerships with Regions, States, and Tribes, as well as engagements with international bodies and the scientific community.

Despite differences across statutes, regulations, policies, and practices, EPA’s programs are committed to using objective, high quality science in Agency decision-making, with uncertainties described and considered, and relevancy to the decision at hand clearly articulated. It is important to recognize that different NAMs are in varying stages of maturity, and to acknowledge and address where information gaps exist. For example, some traditional endpoints of concern (e.g., developmental and reproductive toxicity, immunotoxicity) are inadequately represented in the NAMs space and represent an active area of research. EPA is engaged in the development of novel technologies and approaches to fill these and other information gaps, expanding the foundation for the use of NAMs in decision-making. Along with targeted research to increase NAMs coverage, it is equally important to develop the strategies and frameworks to apply NAMs under different decision contexts (e.g., when dealing with data poor chemicals, or when screening several different chemicals). The Agency continues to innovate in these areas, in part by following the principles laid out in the “Next Generation Blueprint of Computational Toxicology at the US Environmental Protection Agency,” which emphasizes an integrated approach using computational and high-throughput in vitro toxicity testing to inform chemical safety testing and assessment (Thomas 2019). Agency research on the advancement of NAMs is supported, in part, by the Agency’s Strategic Research Action Plan for Chemical Safety and Sustainability and related national research programs that supports NAM development, application, and knowledge sharing and integration (EPA 2022a).

To facilitate the adoption and acceptance of NAMs in regulatory use, it is critical to increase scientific confidence in these new methods. EPA is using NAMs in combination with existing animal-testing data to evaluate the confidence of the use of NAMs in a variety of contexts - including both human health and ecological effects. Demonstrating the applicability and relevance of NAMs in different areas can build confidence and further establish a scientific rationale supporting the use of NAMs in regulatory decision-making. The research efforts on building confidence complement the analyses presented in this report that detail how the EPA’s statutory and regulatory landscape may influence the implementation of NAMs. Ultimately, the research EPA is undertaking today will lead to the acceptance of NAMs as robust approaches to help the Agency better evaluate exposures to, and the potential hazard of, chemicals while reducing reliance on vertebrate animal testing.