# III Regulatory Requirements for Vertebrate Animal Testing

## A Office of Air and Radiation

Among regulations specifying vertebrate animal testing, the Fuel and Fuel Additive Registration requirements are codified in 40 C.F.R. Part 79 Subpart F. In 1994, EPA promulgated these regulations, which require manufacturers of certain fuels and fuel additives to determine the potential public health and environmental effects of these substances through both qualitative exposure analyses and specific vertebrate animal tests and to submit results to EPA. Specifically, the regulations established a tiered testing program that require manufacturers of certain fuels and fuel additives to submit to EPA all Tier 1 (emission characterization) and Tier 2 (specified vertebrate animal testing) data and information. EPA may require alternative testing for any fuel or fuel additive “in lieu of or in addition to standard Tier 2 health testing”. 40 C.F.R. § 79.58(c)(1).

The Significant New Alternatives Policy (SNAP) program was established under the CAA to identify and evaluate substitutes for ozone-depleting substances. The regulations in 40 CFR Part 82 Subpart G require health and safety studies on “the effects of a substitute, its components, its impurities and its degradation products on any organism.” 40 CFR 82.178(a)(7). In addition, 40 CFR 82.178 (a)(7) specifies requirements for submitting a certain minimal amount of vertebrate toxicity testing data: “For tests on mammals, the Agency requires a minimum submission of the following tests to characterize substitute risks: A range-finding study that considers the appropriate exposure pathway for the specific use (e.g., oral ingestion, inhalation, etc.), and a 90-day subchronic repeated dose study in an appropriate rodent species. For certain substitutes, a cardiotoxicity study is also required. Additional mammalian toxicity tests may be identified based on the substitute and application in question. To sufficiently characterize aquatic toxicity concerns, both acute and chronic toxicity data for a variety of species are required. For this purpose, the Agency requires a minimum data set as described in ‘Guidelines for Deriving Numerical National Water Quality Criteria for the Protection of Aquatic Organisms and their Uses’, which is available through the National Technical Information Service (#PB 85–227049)”. The minimum aquatic toxicity data set includes testing in fish.

## B Office of Chemical Safety and Pollution Prevention

The Office of Pesticide Programs (OPP) and the Office of Pollution Prevention and Toxics (OPPT) have promulgated rules that specify the health and safety test guidelines that include vertebrate animal testing to support regulatory decisions under FIFRA, TSCA, and FFDCA in Title 40 of the U.S. Code of Federal Regulations.

For OPP, 40 CFR Part 158, establishes the baseline set of data requirements for pesticides according to use pattern. The regulations also permit OPP to determine data needs according to the sufficiency of existing information and applicability of new data generation impacting registration decisions (40 CFR § 158.30). Further, 40 CFR 158.70 states that "The Agency will determine whether the data submitted or cited to fulfill the data requirements specified in this part are acceptable. This determination will be based on the design and conduct of the experiment from which the data were derived, and an evaluation of whether the data fulfill the purpose(s) of the data requirement." The Agency may require additional data (40 CFR § 158.75) or alternative approaches to fully evaluate a pesticide’s potential to cause adverse effects to human health or the environment. Accordingly, OPP has published several guidance documents to further explain to stakeholders the Agency’s considerations when determining data needs for human health and environmental hazard. These guidance documents are summarized in Appendix A, Table 3. OPPT has promulgated rules which require environmental fate, environmental effects, and health effects testing on chemical substances to determine whether they pose adverse effects (40 CFR Parts 790–799). Detailed summaries of codified data requirements which utilize vertebrate animal testing for both OPP and OPPT are provided in Appendix A, Table 2.

Further, OCSPP has published a master list of harmonized test guidelines for pesticides and toxic substances, which are organized by Series (e.g., Series 830 Product Properties Test Guidelines). The health and safety test guidelines included on the harmonized master list within a series may comprise both vertebrate animal testing and NAMs (e.g., in vitro assays using cells or tissues). This is also the case for the Series 890 Endocrine Disruptor Screening Program Test Guidelines for Tier 1 (Group A) and Tier 2 (Group B) testing requirements. Additionally, OCSPP routinely accepts test data conducted in accordance with Organisation for Economic Co-operation and Development (OECD) test guidelines, as many of these methods are updated to reflect current scientific standards.

## C Office of Land and Emergency Management

RCRA gives EPA the authority to regulate hazardous waste from cradle to grave (Subtitle C). This includes the generation, transportation, treatment, storage, and disposal of hazardous waste. A solid waste is hazardous if it exhibits any RCRA hazardous characteristic or is listed as a hazardous waste. RCRA hazardous characteristics are ignitability, corrosivity, reactivity, or toxicity. For more information, see 40 CFR §§ 261.21, 262.22, 261.23, 261.24 and 40 CFR § 261.11, which outlines the criteria for EPA listing of hazardous waste. In order for EPA to list a solid waste as hazardous, EPA must determine that the solid waste meets one of the following criteria: (1) exhibits any of the characteristics of hazardous waste identified above; (2) meets criteria for designated Acute Hazardous Waste; or (3) meets criteria for designated Toxic Waste. EPA designates an Acute Hazardous Waste based on vertebrate testing in rats and rabbits (40 CFR § 261.11 (a)(2)). EPA designates a Hazardous Waste if the Agency determines that a toxic constituent in the waste “is capable of posing a substantial present or potential hazard to human health or the environment” (40 CFR § 261.11 (a)(3)(i-xi)).

## D Office of Water

Vertebrate animal testing is generally required for whole effluent toxicity (WET) testing. WET is defined as “the aggregate toxic effect of an effluent measured directly by a toxicity test” (40 CFR § 122.2; 54 FR 23868 at 23895, June 2, 1989). Aquatic toxicity test methods designed specifically for measuring WET have been codified at 40 CFR § 136.3 [60 FR 53529; October 16, 1995]. These WET test methods employ a suite of standardized freshwater, marine, and estuarine plants, invertebrates, and vertebrates to estimate acute and short-term chronic toxicity of effluents and receiving waters. Specific test procedures for conducting the approved WET tests are included in three test method manuals. These three method manuals were incorporated into 40 CFR part 136 in the 1995 rule. By regulation, use of these methods and adherence to the specific test procedures outlined in the WET method manuals is generally required when monitoring WET under the National Pollutant Discharge Elimination System (NPDES). See 40 CFR § 136.1(a). NPDES permit writers have the flexibility to choose the most appropriate WET test, taking the sensitivity of species into account. See 40 CFR § 122.44(d)(1)(ii)(“the permitting authority shall use procedures which account for. . . the sensitivity of the species to toxicity testing (when evaluating whole effluent toxicity)”); (“EPA has interpreted [40 § CFR 122.44(d)(1)(ii)] as directing the permitting authority to develop criteria and limits based upon the most sensitive test species to ensure that the most sensitive species and all less sensitive species will be protected.”) 79 FR 49001 at 49005 (August 19, 2014).