# II Environmental Statutes

## A Overview of Major Environmental Statutes

The EPA is responsible for administering a number of environmental laws and major amendments to these statutes since the Agency’s inception in 1970. The statutes provide the EPA with the authority to regulate the nation’s air quality, water quality, pesticides, and industrial chemicals in commerce; and to manage emergency responses, spills, and waste. A summary of EPA’s responsibilities as described in the major environmental statutes to protect human health and the environment is provided in Table 1.

Table 1 Summary of Major Environmental Statutes by Program Office

Statute | Overview | Citation
Office of Air and Radiation (OAR)
Clean Air Act (CAA) | The CAA establishes a variety of authorities and requirements for addressing different types of air pollution from a diverse array of pollution sources. It includes provisions for EPA to identify and evaluate substitutes for ozone-depleting substances that reduce overall risks to human health and the environment, as well as provisions for requiring testing of fuel or fuel additives to determine potential public health and environmental effects of the fuel or additive for the purpose of registration. | 42 U.S.C. §§7401–7671q
Office of Chemical Safety and Pollution Prevention (OCSPP)
Federal Insecticide, Fungicide, and Rodenticide Act (FIFRA) | FIFRA provides for federal regulation of pesticide distribution, sale, and use. All pesticides distributed or sold in the United States must be registered with EPA. To register a pesticide under FIFRA, the applicant must show, among other things, that using the pesticide according to specifications “will not generally cause unreasonable adverse effects on the environment.” | 7 U.S.C. §§136–136y
Federal Food, Drug, and Cosmetic Act (FFDCA) & Food Quality Protection Act (FQPA) | FFDCA (as amended by FQPA) provides EPA with the authority to set tolerances for pesticide residues on food. The Agency must present a safety finding that there is “reasonable certainty that no harm will result from aggregate exposure to the pesticide residue” after considering toxicity, aggregate exposure and special risks to infants and children. | 21 U.S.C. §321q, 21 U.S.C. §346a & Public Law 104–170 (1996)
Endangered Species Act (ESA) | ESA protects and promotes the recovery of species that are in danger of becoming extinct. EPA is directed to ensure that the use of pesticides is not likely to jeopardize the existence of listed species or “destroy or adversely modify” their critical habit. | 42 U.S.C §§1531–1544
Toxic Substances Control Act (TSCA) | TSCA regulates the manufacturing, processing, distribution, use and disposal of chemical substances and mixtures that are not subject to other statutes such as FIFRA or FFDCA. EPA evaluates new and existing chemicals to determine whether they present an unreasonable risk to human health or the environment. As amended by the Frank R. Lautenberg Chemical Safety for the 21^st^ Century Act, TSCA Section 4(h) requires reducing and replacing, to the extent practicable, the use of vertebrate animals in testing. | 15 U.S.C. §§2601–2692
Office of Land and Emergency Management (OLEM)
Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) | CERCLA provides for the cleanup of uncontrolled or abandoned hazardous waste sites as well as accidents, spills, and other emergency releases of hazardous substances. The term “hazardous substance” is defined in Section 101(14) of CERCLA primarily by reference to other environmental statutes and includes substances designated pursuant to CERCLA Section 102. | 42 U.S.C. §§9601–9675
Emergency Planning and Community Right-to-Know Act (EPCRA) | EPCRA requires industry to report on the storage, use and releases of hazardous substances to federal, state, and local governments. EPCRA Section 313 (42 U.S.C. § 11023) established the Toxics Release Inventory (TRI), a publicly available database which tracks the management of toxic chemicals that may pose a threat to human health and the environment. Industrial facilities in covered sectors are required to report releases and management practices for each TRI-listed chemical it manufactures, processes, or uses above the established reporting threshold. | 42 U.S.C. §§11001–11050
Resource Conservation and Recovery Act (RCRA) | RCRA gives EPA the authority to regulate hazardous waste from cradle to grave (Subtitle C). This includes the generation, transportation, treatment, storage, and disposal of hazardous waste. | 42 U.S.C. §§6901–6992k
Office of Water (OW)
Clean Water Act (CWA) | CWA establishes the basic framework for regulating discharges of pollutants into the waters of the United States in a manner that is protective of EPA-approved state and tribal water quality standards for surface waters. Several programs established under the CWA require EPA to consider the toxicity of water pollutants, both chemical and microbial, for example, when setting or reviewing water quality-based standards and reviewing permits. | 33 U.S.C. §§1251–1389
Safe Drinking Water Act (SDWA) | SDWA authorizes EPA to set National Primary Drinking Water Regulations (NPDWRs) to protect against both naturally occurring and synthetic contaminants that may be found in drinking water. | 42 U.S.C. §§300f-300j-26

## B Key Statutory Language Regarding Testing Requirements

EPA’s review of key environmental laws shows that the statutory language provides the Agency broad discretion to address the scientific information and data needed to accomplish the diverse regulatory activities across all program offices. The majority of the statutes do not specify the types of testing required or mandate vertebrate animal testing for a particular regulation, providing the Agency with flexibility to use NAMs for decision-making. However, there are instances where the statutory language broadly describes data (both vertebrate and non-vertebrate testing) the Agency may utilize for regulatory decisions as well as specific circumstances where testing is required. To highlight the unique language across the environmental statutes for varying decision contexts, key references are detailed and grouped into the following three categories: i) general testing requirements; ii) specific testing requirements; and iii) requirements to reduce vertebrate animal testing.

### i General Testing Requirements

- CAA Section 612 requires the EPA to identify and evaluate substitutes for ozone-depleting substances that reduce the overall risks to human health and the environment. Further, Section 612 requires chemical producers to submit their “unpublished health and safety studies” on any chemical substitutes for a class I substance (see 42 U.S.C. 7671a(a) and Appendix A to subpart A of 40 CFR Part 82) to the Agency. 42 U.S.C. § 7671k.
- Under EPCRA, the EPA updates the TRI through Agency-initiated action or petition. EPCRA Section 313(d)(2) provides the criteria for listing a chemical substance on the TRI and states that determinations for addition of chemicals “shall be based on generally accepted scientific principles or laboratory test, or appropriately designed and conducted epidemiological or other population studies, available to the Administrator. . . .” 42 U.S.C. § 11023(d)(2).
- FIFRA Section 3(c)(2)(A) requires EPA to “publish guidelines specifying the kinds of information which will be required to support the registration of a pesticide and shall revise such guidelines from time to time.” 7 U.S.C. § 136a(c)(2)(A). Similarly, the amendment to FFDCA Section 408(p)(1) by the FQPA directed EPA to “develop a chemical screening program, using appropriate validated test systems and other scientifically relevant information, to determine whether certain substances may have an effect in humans that is similar to an effect produced by a naturally occurring estrogen, or such other endocrine effects as [EPA] may designate.” 21 U.S.C. § 346a(p)(1).
- When setting NPDWRs, SDWA Section 1411 requires EPA to use “(i) the best available, peer-reviewed science and supporting studies conducted in accordance with sound and objective scientific practices; and (ii) data collected by accepted methods or best available methods (if the reliability of the method and the nature of the decision justifies use of the data).” 42 U.S.C. § 300g-1(b)(3)(A).
- Further, CWA Section 304(a) requires EPA to develop and publish criteria for water quality that accurately reflect “latest scientific knowledge.” 33 U.S.C. § 1314(a).

### ii Specific Testing Requirements

- CAA Section 211(b)(2)(A) directs the EPA, on a regular basis, to require “the manufacturer of any fuel or fuel additive to conduct tests to determine potential public health and environmental effects of the fuel or additive (including carcinogenic, teratogenic, or mutagenic effects)” for the purpose of registration. 42 U.S.C. § 7545(b)(2)(A). Further, CAA Section 211(b)(2)(B) requires tests “to be conducted in conformity with test procedures and protocols established by the Administrator.” 42 U.S.C. 7545(b)(2)(B). Manufacturers conduct tests on animals using “procedures and protocols” specified in regulations that took effect in 1994; however, no animal testing has been conducted since 2016 because fuels and fuel additives registered after this date have been able to rely on previous animal testing.
- TSCA Section 4(a)(1)(A)(i)(I-III) authorizes EPA to require testing on health or environmental effects of chemical substances and mixtures where the Agency finds that: (I) the manufacture, distribution in commerce, processing, use, or disposal (or any combination of such activities) of a chemical substance or mixture may present an unreasonable risk to health or the environment; (II) there is insufficient information to reasonably determine or predict health or environmental effects from such activities; and (III) testing is necessary to develop such information. 15 U.S.C. § 2603(a)(1)(A)(i)(I-III).
- TSCA Section 4(a)(1)(A)(ii)(I-III) contains similar authority to the provision above, with the exception of Section 4(a)(1)(A)(ii)(I), which authorizes testing when a chemical substance or mixture “is or will be produced in substantial quantities, and (aa) it enters or may reasonably be anticipated to enter the environment in substantial quantities or (bb) there is or may be significant or substantial human exposure to such substance or mixture. . . .” 15 U.S.C. § 2603(a)(1)(A)(ii)(I). TSCA Section 4(a)(1)(B) specifies that to require testing for mixtures, the effects described in Section 4(a)(1)(A)(i)(II) and 4(a)(1)(A)(ii)(II) “may not be reasonably and more efficiently determined or predicted by testing the chemical substances which comprise the mixture.” When the Agency makes these findings, EPA must address this information gap by issuing a rule, order, or consent agreement to require such testing on the substance or mixture to develop information relevant to inform a determination whether the manufacture, distribution in commerce, processing, use, or disposal of such substance or mixture, or that any combination of such activities, does or does not present an unreasonable risk of injury to health or the environment. Section 4(a)(3) stipulates that in cases where the Agency requires the development of new information on a chemical substance, EPA must “explain the basis for any decision that requires the use of vertebrate animals. . . .” 15 U.S.C. § 2603(a)(3).
- TSCA Section 4(a)(2) provides rulemaking authority to: (i) obtain test information to be used to prioritize chemicals for further evaluation, to conduct risk evaluations, and to implement rulemaking for existing chemicals under TSCA Section 6; (ii) to review a new chemical notice or implement a requirement in a consent agreement, test order, or rule under TSCA Section 5; and (iii) to meet regulatory testing needs of another Federal authority with regard to toxicity and exposure. Further, TSCA provides flexibility for determining the appropriate methods and protocols for generating necessary information on the health and environmental effects of the substance or mixture. Section 4(b)(2)(A) states that “epidemiological studies, tiered testing, in vitro tests, and whole animal tests” may be utilized to evaluate health and environmental effects. 15 U.S.C. § 2603(b)(2)(A).

### iii Requirements to Reduce Vertebrate Animal Testing

- TSCA Section 4(h)(1) directs the Agency to reduce vertebrate animal testing, “to the extent practicable, [and] scientifically justified.” Accordingly, the Agency must consider available toxicity information, computational approaches, and high-throughput in vitro screening methods before requesting testing on vertebrate animals.
- TSCA Section 4(h)(1)(B) encourages the use of alternative test methods that reduce or replace vertebrate animals if the information provided is “of equivalent or better scientific quality and relevance for assessing risks of injury to health or the environment . . .” 15 U.S.C. § 2603(h)(1)(B). To facilitate the incorporation of NAMs in Agency decisions, TSCA Section 4(h)(2)(A), directed EPA to develop a strategic plan to “promote the development and implementation of alternative test methods and strategies to reduce, refine, or replace vertebrate animal testing” and to publish a list of NAMs (EPA 2021b) the Agency has determined to be “scientifically reliable, relevant, and capable or providing information of equivalent or better scientific reliability and quality. . . .” 15 U.S.C. § 2603(h)(2)(A,C). (EPA 2018a).
- For new chemicals or significant new uses of chemicals, TSCA does not specify a baseline set of data requirements for their submission; however, manufacturers and importers are required to submit information on the health and environmental effects of the new chemical substance that is in their possession or control, including any reasonably ascertainable information. Further, Section 4(h)(3)(A) directs submitters to utilize any NAMs included on the Agency’s list before generating information using vertebrate animals.