# I Introduction

The United States Environmental Protection Agency (EPA)’s New Approach Methods (NAMs) Work Plan was created to inform Agency efforts toward activities that aim to reduce the use of vertebrate animal testing while continuing to protect human health and the environment (EPA 2021a). NAMs are defined in the NAMs Work Plan as any technology, methodology, approach, or combination that can provide information on chemical hazard and risk assessment to avoid the use of animal testing. The Office of Research and Development (ORD) and the Office of Chemical Safety and Pollution Prevention (OCSPP) developed the NAMs Work Plan with coordination from experts across the Agency. The NAMs Work Plan documents EPA’s current and future activities and strategies aimed at establishing scientific confidence in NAMs and applying NAMs to inform regulatory decisions. The first NAMs Work Plan was released in June 2020 and updated in December 2021.

One of the five objectives of the NAMs Work Plan is to evaluate the regulatory flexibility for accommodating NAMs. EPA operates under laws and regulations that provide the authority and framework for the Agency’s regulatory and research programs. Statutes are laws written and enacted by the legislative branch of government, whereas regulations are written by agencies, such as the EPA, to provide additional interpretation of the laws that were passed by the legislature. In developing the NAMs Work Plan, representatives from the EPA performed an initial survey of the statutes and regulations that govern the Agency’s actions to evaluate the flexibility for accommodating NAMs. The overall conclusion from that initial survey was that the current statutes do not prevent the Agency from considering NAMs when carrying out its responsibilities. However, the initial survey identified some regulations that require vertebrate animal testing. The focus of this report is to expand on the initial survey and provide a comprehensive review of the existing statutes and regulations that inform vertebrate animal testing requirements, which may or may not allow flexibility for implementation of NAMs. The report also includes a review of the Agency’s current utilization of NAMs for regulatory purposes. Subject matter experts across the Agency have provided their analysis of the regulatory landscape in their respective offices.