# IX Acknowledgements

## Report Development and Writing Team

### Office of Research and Development

- Russell Thomas
  Louis D’Amico
  Angelica Frederick
  Annette Guiseppi-Elie
  Alison Harrill

### Office of Air and Radiation

- Jim Caldwell
  Rich Cook (retired)
  Kurt Gustafson
  Bob Hetes (retired)
  Leif Hockstad
  Bella Maranion
  Vicky Mei
  Margaret Sheppard
  Joe Sopata

### Office of Chemistry Safety and Pollution Prevention

- Anna Lowit
  Monique Perron
  Iris Camacho
  Gino Scarano (retired)
  Lindsay O’Dell

### Office of Land and Emergency Management

- Stiven Foster

### Office of Water

- Colleen Flaherty
  Michael Elias

### Office of General Counsel

- Shannon Rebersak
  Alyssa Gsell
  Susmita Dubey (retired)
  Seth Nolbaum
  Winifred Okoye
  Melina Williams